# Acronyms

ARMD: Atrophic retinal macular degeneration

BAT: Brightness acuity tester

BFE: Blue field entoptoscope

BUN: Blood-urea-nitrogen

CF: Count fingers

CI: Clinical index

CNS: Central nervous system

CS: Contrast sensitivity

CSF: Contrast sensitivity function

ECCE: Extracapsular cataract extraction

ERG: Electroretinogram

GDCS: Glare disability as measured by reduction in contrast sensitivity

GDVA: Glare disability as measured by reduction in visual acuity

HM: Hand motion

ICCE: Intracapsular cataract extraction

IOL: Intraocular lens

IOP: Intraocular pressure

LP: Light perception

MD: Macular degeneration

Nd:YAG: Neodymium:yttrium aluminum garnet

NHANES: National Health and Nutrition Examination Survey

PAM: Potential acuity meter

PCO: Posterior capsular opacification

PE: Phacoemulsification

PORT: Patient Outcomes Research Team

PSC: Posterior subcapsular

Se: Sensitivity

SMD: Senile macular degeneration

Sp: Specificity

TVA: True Vision Analyzer

UV-B: Ultraviolet-B

VA: Visual acuity

VEP: Visually evoked potentials

VER: Visually evoked responses

YAG: Yttrium aluminum garnet