# Suggested Reading

Balzer M. Personality coping factors and problem-solving ability in older outpatient cataract removal patients [dissertation]. Madison: University of Wisconsin-Madison; 1988. Available from: Dissertation Information Services, 300 N. Zeeb Road, Ann Arbor, MI 48106; no. 8810445.
Bernth-Petersen P. The effectiveness of cataract surgery. A retrospective study. Acta Ophthalmol (Copenh) 1981 Feb;59(1):50-6.
Bernth-Petersen P, Bach E. Epidemiologic aspects of cataract surgery. II. Regional variation in frequencies. Acta Ophthalmol (Copenh) 1983 Jun;61(3):397-405.
Brilliant GE, Brilliant LB. Using social epidemiology to understand who stays blind and who gets operated for cataract in a rural setting. Soc Sci Med 1985;21(5):553-8.
Burrows J, Briggs RS, Elkington AR. Cataract extraction and confusion in elderly patients. J Clin Exp Gerontol 1985;7(1):51-70.
Cheng H, McPherson K, Bron AJ. Use of a grading system in the evaluation of complications in a randomized controlled trial on cataract surgery. Br J Ophthalmol 1986;70(6):411-7.
Clayman HM, Jaffe NS, Jaffe MS, Luscombe SM. Bilateral intraocular lens implantation. Ophthalmology 1983 Apr;90(4):321-3.
Cooper AF, Porter R. Visual acuity and ocular pathology in the paranoid and affective psychoses of later life. J Psychosom Res 1976;20(2):107-14.
DeBlase R, Badziong MR, Jones SL. Postintraocular lens implants: needs of patients. Geriatric Nursing: Am J Care Aging 1988 Nov-Dec;9(6):342-3.
Dickinson TD. Intraocular lens implant - Visual success, psychological complication. Am J Ophthalmol 1978 Dec;86(6):847.
DiStefano AF, Aston SJ. Aging and rehabilitation: advances in the state of the art. In: Brody SJ, Ruff GE, editors. Rehabilitation for the blind and visually impaired elderly. New York: Springer Publishing Company; 1986. p. 203-17.
Dodick JM. Ambulatory cataract surgery: a hospital-based approach. Trans New Orleans Acad Ophthalmol 1988;36:47-51.
Elam JT, Applegate WB, Miller ST, Baker M, Blow F. Impact of cataract surgery and lens implantation on overall function in a group of elderly patients. Gerontologist 1984;24:269.
Elliott AJ. Poor vision and the elderly—a domiciliary study. Eye 1989;3(Pt 3):365-9.
Greenblatt SL. Physicians and chronic impairment: a study of ophthalmologists' interactions with visually impaired and blind patients. Soc Sci Med 1988;26:393-9.
Greenblatt SL. Teaching ophthalmology residents about rehabilitation. Ophthalmology 1988 Oct;95(10):1468-72.
Haavisto MV, Heikinheimo RJ, Mattila KJ, Rajala SA. Living conditions and health of a population aged 85 years or over: a five year followup study. Age Ageing 1985;14:202-8.
Harding JJ. India-US case-control study of age-related cataracts. Arch Ophthalmol 1990 Jan;108(1):13-4.
Joseph N, David R. Bilateral cataract extraction in one session: report on five years' experience. Br J Ophthalmol 1977 Oct;61(10):619-21.
Karhunen U, Orko R. Psychiatric reactions complicating cataract surgery - a prospective-study. Ophthalmic Surg 1982 Dec;13(12):1008-12.
Lagoe RJ, Milliren JW. A community-based analysis of ambulatory surgery utilization. Am J Public Health 1986 Feb;76(2):150-3.
Pellegrino ED, Thomasma DC. For the patient's good. The restoration of beneficence in health care. New York: Oxford University Press; 1988.
Ratzan RM. Communication and informed consent in clinical geriatrics. Int J Aging Human Dev 1986;23(1):17-26.
Sappenfield DL, Driebe WT Jr. Resident extracapsular cataract surgery: results and a comparison of automated and manual techniques. Ophthalmic Surg 1989 Sep;20(9):619-24.
Shanahan M, Pelham VM. Coming out of the process: nursing evaluation of the care of patients with cataracts. QRB Qual Rev Bull 1978 Mar;4(5):8-10.
Sindberg EJ. A long-term followup of cataract extraction with and without intraocular lens implantation. Acta Ophthalmol (Copenh) 1983 May-Aug;61:576-82.
Stone LS, Oldenkamp SM, Fritz KJ. Behavioral disturbance following intraocular lens implantation. Ann Ophthalmol 1983;15:946-7.
Sutherland A, Karlinsky H. Abrupt recognition of age-related physical changes in appearance following cataract surgery - a case report. J Am Geriatr Soc 1989 May;37(5):447-9.
Ultraviolet radiation and formation of cataracts. N Engl J Med 1989 May 11;320(19):1285-6.
Veatch RM. A theory of medical ethics. New York: Basic Books; 1981.
Veatch RM. The foundations of justice: why the retarded and the rest of us have claims to equality. New York: Oxford University Press; 1986.
Verma S. Caring for nursing home residents means caring for their vision. Nurs Homes 1985 Nov-Dec;34(6):39-40.
Wainapel ST, Young SK, Frazzari PJ. Severe visual impairment on a rehabilitation unit: incidence and implications. Arch Phys Med Rehabil 1989;70:439-41.
Wong WW. Indications for cataract surgery - psycholinguistic considerations. Arch Ophthalmol 1978 Mar;96(3):526-8.
Yanoff M. Cataract surgery—when and how. Geriatrics 1982;37:71-3.
Zaner RM. Ethics and the clinical encounter. Englewood Cliffs (NJ): Prentice Hall, Inc.; 1988.
Zaner RM. Medicine and dialogue. J Med Philos 1990 Jun;15(3):303-25.
Zavon B, Slater N. A surgical counseling plan for patients undergoing cataract surgery. J Ophthal Nurs Technol 1988 Mar-Apr;7(2):68-71.