# References

Abrahamsson M, Sjostrand J. Impairment of contrast sensitivity function (CSF) as a measure of disability glare. Invest Ophthalmol Vis Sci 1986 Jul;27(7):1131-6.
Acheson J, McHugh J, Falcon M. Changing patterns of early complications in cataract surgery with new techniques: a surgical audit. Br J Ophthalmol 1988 Jun;72(6):481-4.
Adams DF, Shock JP. Prediction of postoperative visual acuity in cataract patients using the Flying Corpuscle Viewer. Ophthalmic Surg 1986 Aug;17(8):509-12.
Adamsons I, Munoz B, Enger C, Taylor HR. Prevalence of lens opacities in surgical and general populations. Arch Ophthalmol 1991 Jul;109(7):993-7.
Adamsons I, Rubin GS, Vitale S, Taylor HR. The effect of early cataracts on glare and contrast sensitivity: a pilot study. Arch Ophthalmol 1992 Aug;110(8):1081-6.
Albert DW, Wade EC, Parrish RK 2d, Flynn HW Jr, Slomovic AR, Tanenbaum M, Blodi C. A prospective study of angiographic cystoid macular edema one year after Nd:YAG posterior capsulotomy. Ann Ophthalmol 1990 Apr;22(4):139-43.
Allen AW, Zhang HR. Extracapsular cataract extraction: prognosis and complications with and without posterior-chamber lens implantations. Ann Ophthalmol 1987;19:329-33.
Ambler JS, Constable IJ. Retinal detachment following Nd:YAG capsulotomy. Aust N Z J Ophthalmol 1988 Nov;16(4):337-41.
American Academy of Ophthalmology. Ophthalmic Procedures Assessment. Contrast sensitivity and glare testing in the evaluation of anterior segment disease. Ophthalmology 1990 Sep;97(9):1233-7.
American Academy of Ophthalmology. Policy statement on cataract surgery in the otherwise healthy adult second eye. San Francisco: American Academy of Ophthalmology; 1991.
American Academy of Ophthalmology, Quality of Care Committee, Anterior Segment Panel.Cataract in the otherwise healthy adult eye. San Francisco: American Academy of Ophthalmology; 1989. 12 p. A Preferred Practice Pattern approved by the Board of the Academy, September 16, 1989.
American Cancer Society. Summary of current guidelines for the cancer-related checkup: recommendations. Atlanta: American Cancer Society; 1988.
American College of Physicians, Clinical Efficacy Project. Clinical efficacy reports. Philadelphia: American College of Physicians; 1987.
American College of Physicians, Health and Public Policy Committee. Comprehensive functional assessment for elderly patients. Ann Intern Med 1988 Jul 1;109(1):70-2.
American College of Physicians, Medical Practice Committee. Periodic health examination: a guide for designing individualized preventive health care in the asymptomatic patient. Ann Intern Med 1981 Dec;95(6):729-32.
American College of Physicians. Preoperative pulmonary function testing: position paper [comment]. Ann Intern Med 1990 May 15;112(10):793-4.
American Geriatrics Society. Screening for cervical carcinoma in elderly women. Developed by the Clinical Practice Committee and approved by the American Geriatric Society Board of Directors. J Am Geriatr Soc 1989 Sep;37(9):885-7.
Angra SK, Pal BK. Visual acuity testing in cataract—an insight (Cataract classification density based). Indian J Ophthalmol 1990 Oct-Dec;38(4):153-5.
Applegate WB, Miller ST, Elam JT, Freeman JM, Wood TO, Gettlefinger TC. Impact of cataract surgery with lens implantation on vision and physical function in elderly patients. JAMA 1987 Feb 27;257(8):1064-6.
Arnott E, Condon R. The totally encircling loop lens. Follow-up of 1800 cases. Cataract 1985 Oct;2(8):13-8.
Arnott EJ, Grindle CF, Krolman GM. Four and one-half year study of the relationship between one-piece encircling loop polymethylmetharcylate lenses and retinal detachment. J Cataract Refract Surg 1988 Jul;14(4):387-92.
Aron-Rosa DS. Influence of picosecond and nanosecond YAG laser capsulotomy on intraocular pressure. J Am Intraocul Implant Soc 1985 May;11(3):249-52.
Axt JC. Nd:YAG laser posterior capsulotomy: a clinical study. Am J Optom Physiol Opt 1985 Mar;62(3):173-87.
Axt JC. Longitudinal study of postoperative astigmatism. J Cataract Refract Surg 1987 Jul;13(4):381-8.
Azen SP, Hurt A, Steel D, Wilson J, Reinig J, Bernstein J, Bedi M, Smith RE. Effects of the Shearing posterior chamber intraocular lens on the corneal endothelium. Am J Ophthalmol 1983 Jun;95(6):798-802.
Backer CL, Tinker JH, Robertson DM, Vliestra RE. Myocardial reinfarction following local anesthesia for ophthalmic surgery. Anesth Analg 1980 Apr;59(4):257-62.
Baraldi P, Enoch JM, Raphael S. Vision through nuclear and posterior subcapsular cataract. Int Ophthalmol 1986 May;9(2-3):173-8.
Barrett GD, Beasley H, Lorensetti OJ, Rosenthal A. Multicenter trial of an intraocular hydrogel lens implant. J Cataract Refract Surg 1987 Nov;13(6):621-6.
Barrett GD, Constable IJ, Steward AD. Clinical results of hydrogel lens implantation. J Cataract Refract Surg 1986 Nov;12(6):623-31.
Bates AK, Cheng H. Bullous keratopathy: a study of endothelial cell morphology in patients undergoing cataract surgery. Br J Ophthalmol 1988 June;72(6):409-12.
Bates AK, Cheng H, Hiorns RW. Pseudophakic bullous keratopathy: relationship with endothelial cell density and use of a predictive cell loss model. A preliminary report. Curr Eye Res 1986 May;5:363-6.
Bates B. A guide to physical examination and history taking. 4th ed. Philadelphia: Lippincott; 1987. p. 20-7.
Bath PE, Fankhauser F. Long-term results of Nd:YAG laser posterior capsulotomy with the Swiss laser. J Cataract Refract Surg 1986 Mar;12(2):150-3.
Benerza D, Chirambo MC. Bilateral versus unilateral cataract extraction: advantages and complications. Br J Ophthalmol 1978 Nov;62(11):770-3.
Bernth-Petersen P. Visual functioning in cataract patients. Methods of measuring and results. Acta Ophthalmol (Copenh) 1981;59:198-205.
Bernth-Petersen P. Outcome of cataract surgery. II. Visual functioning in aphakic patients. Acta Ophthalmol (Copenh) 1982 Apr;60(2):243-52.
Bernth-Petersen P. Cataract surgery. Outcome assessments and epidemiologic aspects. Acta Ophthalmol Suppl (Copenh) 1985;174:3-47.
Bernth-Petersen P, Naeser K. Clinical evaluation of the Lotmar visometer for macular testing in cataract patients. Acta Ophthalmol (Copenh) 1982 Aug;60(4):525-32.
Bezan D. Management of patients with age-related cataracts: a survey of Oklahoma optometrists. J Am Optom Assoc 1987 Feb;58(2):100-4.
Bhatnagar R, West KP Jr, Vitale S, Sommer A, Joshi S, Venkataswamy G. Risk of cataract and history of severe diarrheal disease in Southern India. Arch Ophthalmol 1991 May;109(5):696-9.
Black RL, Oglesby RB, von Sallman L, Bunim JJ. Posterior subcapsular cataracts induced by corticosteroids in patients with rheumatoid arthritis. JAMA 1960 Sep 10;174(2):166-71.
Blery C, Charpak Y, Szatan M, Darne B, Fourgeaux B, Chastang C, Gaudy JH. Evaluation of a protocol for selective ordering of preoperative tests. Lancet 1986 Jan 18;1(8473):139-41.
Bloom BS, Krueger N. Cost and quality effects of outpatient cataract removal. Inquiry 1988 Fall;25(3):383-7.
Bochow TW, West SK, Azar A, Munoz B, Sommer A, Taylor HR. Ultraviolet light exposure and risk of posterior subcapsular cataracts. Arch Ophthalmol 1989 Mar;107(3):369-72.
Boen-Tan TN, Stilma JS. Prevention of IOP-rise following Nd-YAG laser capsulotomy with pre-operative timolol eye-drops and 1 tablet acetazolamide 250 mg systematically. Doc Ophthalmol 1986 Dec 30;64(1):59-67.
Born CP, Ryan DK. Effect of intraocular lens optic design on posterior capsular opacification. J Cataract Refract Surg 1990 Mar;16(2):188-92.
Bourne WM, Kaufman HE. Cataract extraction and the corneal endothelium. Am J Ophthalmol 1976 July;82(1):44-7.
Brilliant LB, Grasset NC, Pokhrel RP, Kolstad A, Lepkowski JM, Brilliant GE, Hawks WN. Associations among cataract prevalence, sunlight hours, and altitude in the Himalayas. Am J Epidemiol 1983 Aug;118(2):250-64.
Brint SF, Ostrick DM, Bryan JE. Keratometric cylinder and visual performance following phacoemulsification and implantation with silicone small-incision or poly(methyl methacrylate) intraocular lenses. J Cataract Refract Surg 1991 Jan;17(1):32-6.
Brown NA, Sparrow JM. Control of astigmatism in cataract surgery. Br J Ophthalmol 1988 Jul;72(7):487-93.
Brown RH, Stewart RH, Lynch MG, Crandall AS, Mandell AI, Wilensky JT, Schwartz AL, Gaasterland DE, DeFaller, JM, Higginbotham EJ. ALO 2145 reduces the intraocular pressure elevation after anterior segment laser surgery. Ophthalmology 1988 Mar;95(3):378-84.
Brown SV, Thomas JV, Belcher CD, Simmons RJ. Effect of pilocarpine in treatment of intraocular pressure elevation following neodymium:YAG laser posterior capsulotomy. Ophthalmology 1985 Mar;92(3):354-9.
Bryant WR. The Haag-Streit Lotmar visometer for determining macular potential prior to cataract surgery. J Am Intraocul Implant Soc 1985 Nov;11(6):581-3.
Bukelman A, Hoffman P, Oliver M. Limited choroidal hemorrhage associated with extracapsular cataract extraction. Arch Ophthalmol 1987 Mar;105(3):338-41.
Burratto L, Ricci A, Vitali D. Use of the YAG laser with a seven-micron spot in pseudophakic eyes. J Am Intraocul Implant Soc 1985 Nov;11(6):574-6.
Canadian Task Force on the Periodic Health Examination.The periodic health examination: 2. 1989 update. Can Med Assoc J 1989 Aug 1;141(3):209-16.
Canadian Task Force on the Periodic Health Examination. Periodic health examination, 1991 update: 1. Screening for cognitive impairment in the elderly. Can Med Assoc J 1991 Feb 15;144(4):425-31.
Canning CR, Capon MR, Sherrard ES, Kerr Muir MG, Pearson R, Cooling RJ. Neodymium:YAG laser iridotomies—short-term comparison with capsulotomies and long-term followup. Graefes Arch Clin Exp Ophthalmol 1988;226(1):49-54.
Capone A Jr, Rehkopf PG, Warnicki JW, Stuart JC. Temporal changes in posterior capsulotomy dimensions following neodymium:YAG laser discission. J Cataract Refract Surg 1990 Jul;16(4):451-6.
Carpel EF, Henderson V. The influence of cataract types on potential acuity meter results. J Cataract Refract Surg 1986 May;96(12):375-81.
Carriker F, Liebowitz S, Nees O, Siegel E, Duzman E, Cheetham JK, DeGryse R. Prednisolone acetate-Gentamicin combination following cataract surgery. Ann Ophthalmol 1987;19(7):247-50.
Carver JA. Cataract care made plain. Am J Nursing 1987 May;87(5):626-30.
Chambless WS. Neodymium:YAG laser posterior capsulotomy results and complications. J Am Intraocul Implant Soc 1985 Jan;11(1):31-2.
Channell MM, Bechman H. Intraocular pressure changes after neodymium-YAG laser posterior capsulotomy. Arch Ophthalmol 1984 Jul;102(7):1024-6.
Charpole Y, Blery C, Chastang CG, Szatan M, Fourgeaux B. Prospective assessment of a protocol for selective ordering of pre-operative chest x-rays. Can J Anaesth 1988 May;35(3 Pt 1):259-64.
Chatterjee A, Milton RC, Thyle S. Prevalence and aetiology of cataract in Punjab. Br J Ophthalmol 1982 Jan;66(1):35-42.
Cheng H. Current status of cataract surgery--a review of personal experience. Eye 1987;1(1):551-6.
Christen WG, Manson JE, Seddon JM, Glynn RJ, Buring JE, Rosner B, Hennekens CH. A prospective study of cigarette smoking and risk of cataract in men. JAMA 1992 Aug 26;268(8):989-93.
Christenbury JD, McPherson SD. Potential acuity meter for predicting postoperative visual acuity in cataract patients. Am J Ophthalmol 1985 Mar;99(3):365-6.
Chylack LT Jr, Leske MC, Khu P, McCarthy D, Wu SY. Strategies for measuring the rate of age-related cataract formation in vivo. Lens Eye Toxic Res 1989;6(4):515-22.
Chylack LT Jr, Leske MC, Sperduto R, Khu P, McCarthy D. Lens Opacities Case-Control Study Group. Lens opacities classification system. Arch Ophthalmol 1988 Mar;106(3):330-4.
Cink DE, Sutphin JE. Quantification of the reduction of glare disability after standard extracapsular cataract surgery. J Cataract Refract Surg 1992 Jul;18:385-90.
Cinotti DJ, Fiore PM, Maltzman BA, Corstad WH, Cirotti AA. Control of intraocular pressure in glaucomatous eyes after extracapsular cataract extraction with intraocular lens implantation. J Cataract Refract Surg 1988 Nov;14(6):650-3.
Clayman HM, Jaffe NS, Light DS, Eichenbaum DM. Lens implantation surgery in the second eye. Ophthalmic Surg 1977 Jun;8(3):45-8.
Clayton RM, Cuthbert J, Duffy J, Seth J, Phillips CI, Bartholomew RS, Reid JM. Some risk factors associated with cataract in S.E. Scotland: a pilot study. Trans Ophthalmol Soc U K 1982 102(Pt 3);331-6.
Clayton RM, Cuthbert J, Seth J, Phillips CI, Bartholomew RS, Reid JM. Epidemiological and other studies in the assessment of factors contributing to cataractogenesis. Ciba Found Symp 1984 106:25-47.
Clorfeine GS, Parker WT. YAG capsulotomy and IOP rise [letter]. Ophthalmic Surg 1984 Jul 15(7):610-1.
Cohen DL, Neil HA, Sparrow J, Thorogood M, Mann JI. Lens opacity and mortality in diabetes. Diabetic Med 1990 Apr;7:615-7.
Cohen MM. Laser interferometry: evaluation of potential visual acuity in the presence of cataracts. Ann Ophthalmol 1976 Jul;8(7):845-9.
Collman GW, Shore DL, Shy CM, Checkoway H, Luria AS. Sunlight and other risk factors for cataracts: an epidemiologic study. Am J Public Health 1988 Nov;78(11):1459-62.
Coonan P, Fung WE, Webster RG Jr, Allen AW Jr. The incidence of retinal detachment following extracapsular cataract extraction. A ten-year study. Ophthalmology 1985 Aug;92(8):1096-101.
Corboy JM, Novak EA Jr. Neodymium:YAG laser capsulotomy with a biconvex intraocular lens. J Cataract Refract Surg 1989 Jul;15(4):435-6.
Cory CC. Prevention and treatment of postimplantation astigmatism. J Cataract Refract Surg 1989 Jan;15(1):58-60.
Cruz RD, Adachi-Usami E. Quantitative evaluation of electroretinogram before cataract surgery. Jpn J Ophthalmol 1989;33(4):451-7.
Cunliffe IA, Flanagan DW, George NDL, Aggarwaal RJ, Moore AT. Extracapsular cataract surgery with lens implantation in diabetics with and without proliferative retinopathy. Br J Ophthalmol 1991 Jan;75(1):9-12.
Dana MR, Tielsch JM, Enger C, Joyce E, Antoli JM, Taylor HR. Visual impairment in a rural Appalachian community. Prevalence and causes. JAMA 1990 Nov 14;264(18):2400-5.
Dardenne MU, Gerten GJ, Kokkas K, Kermani O. Retrospective study of retinal detachment following neodymium:YAG laser posterior capsulotomy. J Cataract Refract Surg 1989 Nov;15(6):676-80.
Datiles MB, Edwards PA, Kaiser-Kupfer MI, McCain L, Podgor M. A comparative study between PAM and the laser interferometer in cataracts. Graefes Arch Clin Exp Ophthalmol 1987;225(6):457-60.
David R, Tessler Z, Yagev R, Briscoe D, Biedner BZ, Gilad E, Yassur Y. Persistently raised intraocular pressure following extracapsular cataract extraction. Br J Ophthalmol 1990 May;74(5):272-4.
Davies PD, Limacher E, Powell K. Outpatient cataract surgery 1982-1986. Eye 1987;1(Pt 6):728-34.
Davis ET, Sherman J, Bass SJ, Schnider CM. Pre-surgical prediction of post-surgical visual function in cataract patients: multivariate statistical analyses of test measures. Clin Vision Sci 1991;6(3):190-207.
Davison JA. Endothelial cell loss during the transition from nucleus expression to posterior chamber-iris plane phacoemulsification. J Am Intraocul Implant Soc 1984 Winter;10:40-3.
Davison JA. Retinal tears and detachments after extracapsular cataract surgery. J Cataract Refract Surg 1988 Nov;14(6):624-32.
Department of Health and Human Services (US), Office of Inspector General, Office of Analysis and Inspections. Ophthalmology/optometry relationships involved in cataract surgery. Washington: Office of Analysis and Inspections; 1989 Apr. Report No.: OAI-07-88-00460. 17 p.
Deutsch TA, Goldberg MF. Neodymium:YAG laser capsulotomy. Int Ophthalmol Clin 1985 Fall;25(3):87-100.
Dixon WS. Prospective study of corneal astigmatism after standardized cataract incision: a pilot study. Dev Ophthalmol 1989;18:192-6.
Donderi DC, Murphy SB. Predicting activity and satisfaction following cataract surgery. J Behav Med 1983 Sep;6(3):313-28.
Donnelly D. Instilling eyedrops: difficulties experienced by patients following cataract surgery. J Adv Nurs 1987 Mar;12(2):235-43.
Downing JE. Long-term discission rate after placing posterior chamber lenses with the convex surface posterior. J Cataract Refract Surg 1986 Nov;12(6):651-4.
Drummond MF. Measuring the quality of life of people with visual impairment. Proceedings of a workshop. Washington: National Institutes of Health; 1990. NIH Pub. No. 90-3078.
Dubey AK, Masani PH, Shroff AP. Quantitative assessment of conventional macular function tests in cases of cataract. Indian J Ophthalmol 1983;31 Suppl:895-7.
Durham DG, Gills JP. Three thousand YAG lasers in posterior capsulotomies: an analysis of complications and comparison to polishing and surgical discissions. Trans Am Ophthalmol Soc 1985;83:218-35.
Ederer F, Hiller R, Taylor HR. Senile lens change and diabetes in two population studies. Am J Ophthalmol 1981 Mar;91(3):381-95.
Elam JT, Graney MJ, Applegate WB, Miller ST, Freeman JM, Wood TO, Gettlefinger TC. Functional outcome one year following cataract surgery in elderly persons. J Gerontol 1988 Sep;43(5):M122-M126.
Elliott DB, Gilchrist J, Whitaker D. Contrast sensitivity and glare sensitivity changes with three types of cataract morphology: are these techniques necessary in a clinical evaluation of cataract? Ophthalmic Physiol Opt 1989 Jan;9(1):25-30.
Elliott DB, Hurst MA. Assessing the effect of cataract: a clinical evaluation of the Opacity Lensmeter 701. Optom Vis Sci 1989 May;66(5):257-63.
Elliott DB, Hurst MA, Weatherill J. Comparing clinical tests of visual function in cataract with the patient's perceived visual disability. Eye 1990;4(Pt 5):712-7.
Engelbrecht GC, Stulting AA. Bilateral cataract extractions in one session. A report on 134 consecutive cases. S Afr Med J 1984 Jun;65:889-90.
Enoch JM, Bedell HE, Kaufman HE. Interferometric visual acuity testing in anterior segment disease. Arch Ophthalmol 1979 Oct;97(10):1916-9.
Enoch JM, Williams RA, Essock EA, Fendick M, Osbourne NN, Chader GJ.Progress in retinal research. Oxford (NY): Pergamon Press; 1985a. Chapter 3, Hyperacuity: a promising means of evaluating vision through cataract.
Enoch JM, Williams RA, Essock EA, Raphael S. Application of hyperacuity to assess vision through media and retinal opacities: methodology. In: Heyl A, Greve EL, editors. Proceedings of the 6th International Visual Field Symposium. Dordrecht (Netherlands): D.W. Junk Publishers; 1985b. p. 569-75.
Essock EA, Williams RA, Enoch JM, Raphael S. The effects of image degradation by cataract on vernier acuity. Invest Ophthalmol Vis Sci 1984 Sep;25(9):1043-50.
Farrell TA, Deichman CB. Resident cataract surgery. Review of a rural teaching hospital's experience. Ophthalmology 1981 Feb;88(2):114-6.
Faulkner GD. Endothelial cell loss after phacoemulsification and insertion of silicone lens implants. J Cataract Refract Surg 1987 Nov;13(11):649-52.
Faulkner W. Laser interferometric prediction of postoperative visual acuity in patients with cataracts. Am J Ophthalmol 1983 May;95(5):626-36.
Feller BA. Americans needing help to function at home. Hyattsville (MD): National Center for Health Statistics; 1983. Advance Data No. 92.
Fenton PJ, Gardner ID. Simultaneous bilateral intraocular surgery. Trans Ophthalmol Soc U K 1982 Jul;102(Pt 2):298-301.
Ficker LA, Steele ADM. Complications of Nd:YAG laser posterior capsulotomy. Trans Ophthalmol Soc U K 1985;104(Pt 5):529-32.
Fisher SJ, Cunningham RD. The medical profile of cataract patients. Clin Geriatr Med 1985 May;1(2):339-44.
Flaye DE, Sullivan KN, Cullinan TR, Silver JH, Whitelocke RA. Cataracts and cigarette smoking: the City Eye Study. Eye 1989;3(Pt 4):379-84.
Flohr MJ, Robin AL, Kelley JS. Early complications following Q-switched neodymium:YAG laser posterior capsulotomy. Ophthalmology 1985 Mar;92(3):360-3.
Foster A, Johnson GJ. Magnitude and causes of blindness in the developing world. Int Ophthalmol 1990 May;14(3):135-40.
Fourman S, Apisson J. Late onset elevation in intraocular pressure after Neodymium-YAG laser posterior capsulotomy. Arch Ophthalmol 1991 Mar;109(3):511-3.
Frezzotti R, Caporossi A. Pathogenesis of posterior capsular opacification. Part I. Epidemiological and clinico-statistical data. J Cataract Refract Surg 1990 May;16(3):347-52.
Fukuhara J, Oozato H, Nojima S, Saidhin M, Nakao S. Visual-evoked potentials elicited by laser speckle patterns. Studies on the characteristics and assessment of visual function in patients with ocular media opacities. Invest Ophthalmol Vis Sci 1983 Oct;24(10):1400-7.
Galand A, Van Oye R, Budo C, Goes F, Foets B. Results of implantation in the capsular bag. A short term review of 1,588 cases. Trans Ophthalmol Soc U K 1985;104:563-6.
Gardner KM, Straatsma BR, Pettit TH. Neodymium:YAG laser posterior capsulotomy: the first 100 cases at UCLA. Ophthalmic Surg 1985 Jan;16(1):24-8.
Gills JP, Sanders DR. Use of small incisions to control reduced astigmatism and inflammation following cataract surgery. J Cataract Refract Surg 1991;17(Suppl):740-4.
Goldmann H, Chrenkova A, Cornaro S. Retinal visual acuity in cataractous eyes. Determination with interference fringes. Arch Ophthalmol 1980 Oct;98(10):1778-81.
Goldstein J, Jamara RJ, Hecht SD, Liberace AR, Collins KM. Clinical comparison of the SITE IRAS hand-held interferometer and Haag-Streit Lotmar visometer. J Cataract Refract Surg 1988 Mar;14(2):208-11.
Graney MJ, Applegate WB, Miller ST, Elam JT, Freeman JM, Wood TO, Gettlefinger TC. A clinical index for predicting visual acuity after cataract surgery. Am J Ophthalmol 1988 May 15;105(5):460-5.
Graney MJ, Applegate WB, Miller ST, Elam JT, Gettelfinger TC, Wood TO, Freeman JM. An index for estimating probabilities of surgical success for cataract patients with retinal disease. J Gerontol 1990 Mar;45(2):M40-M44.
Green RP Jr, Peters DR. Visual results after cataract surgery by a military resident surgeon. Ophthalmic Surg 1988;19(4):244-8.
Grignolo FM, Moscone F, Sobrero C, Leone M. Evaluation of macular function by Lotmar's visometer test and blue-field entoptic test in patients with cataract. Ann Ophthalmol 1988 Jul;20(7):247-50.
Halliday BL, Ross JE. Comparison of 2 interferometers for predicting visual acuity in patients with cataract. Br J Ophthalmol 1983 May;67(5):273-7.
Hamilton RC, Gimbel HV, Strunin L. Regional anaesthesia for 12,000 cataract extraction and intraocular lens implantation procedures. Can J Anaesth 1988 Nov;35(6):615-23.
Hankinson SE, Willett WC, Colditz GA, Seddon JM, Rosner B, Speizer FE, Stampfer MJ. A prospective study of cigarette smoking and risk of cataract surgery in women. JAMA 1992 Aug 25;268(8):994-8.
Hansen TE, Naeser K, Rask KL. A prospective study of intraocular pressure four months after extracapsular cataract extraction with implantation of posterior chamber lenses. J Cataract Refract Surg 1987 Jan;13(1):35-8.
Hara T. Fate of the capsular bag in endocapsular phacoemulsification and complete in-the-bag intraocular lens fixation. J Cataract Refract Surg 1986 Jul;12(4):408-12.
Hard AL, Abrahamsson M, Sjostrand J. A new glare test based on low contrast letters-evaluation in cataract patients. Acta Ophthalmol (Copenh) 1990 Apr;68(2):145-50.
Hardesty DC. The ophthalmic surgical patient. In: Wolfstahl SD, editor. Medical perioperative management. Norwalk (CT): Appleton & Lang; 1989. p. 417-26.
Harding JJ, van Heyningen R. Beer, cigarettes and military work as risk factors for cataract development. Dev Ophthalmol 1989;17:13-6.
Harris WS, Herman WK, Fagadau WR. Management of the posterior capsule before and after the YAG laser. Trans Ophthalmol Soc U K 1985;104(Pt 5):533-5.
Harris WS, Kogan I. Retrospective study of retinal complications with posterior chamber lens. Contact Intraocul Lens Med J 1981 Oct-Dec;7(4):341-4.
Harrison RJ, Wild JM, Hobley AJ. Referral patterns to an ophthalmic outpatient clinic by general practitioners and ophthalmic opticians and the role of these professionals in screening for ocular disease. BMJ 1988 Nov 5;297(6657):1162-7.
Hayward RS, Steinberg EP Ford DE, Roizen MF, Roach KW. Preventive care guidelines: 1991. Ann Intern Med 1991 Aug 15;114(9):758-83.
Health Care Financing Administration. Summarized From 100% File, Part B Medicare Annual Data System File, 1990, 1991.
Henderson JH. Simultaneous bilateral cataract extraction. Trans Ophthalmol Soc N Z 1977;29:81-2.
Heslin KB, Guerriero PN. Clinical retrospective study comparing planned extracapsular cataract extraction and phacoemulsification with and without lens implantation. Ann Ophthalmol 1984 Oct;16(10):956-8, 960-2.
Hess R, Woo G. Vision through cataracts. Invest Ophthalmol Vis Sci 1978 May;17(5):428-35.
Hilbourne JHF. Social and other aspects of adjustment to single eye cataract extraction in elderly patients. Trans Ophthalmol Soc U K 1975;95:254-9.
Hill BJ. Sensory information, behavioral instructions and coping with sensory alteration surgery. Nurs Res 1982;31:17-21.
Hiller R, Sperduto RD, Ederer F. Epidemiologic associations with cataract in the 1971-1972 National Health and Nutrition Examination Survey. Am J Epidemiol 1983 Aug;118(2):239-49.
Hiller R, Sperduto RD, Ederer F. Epidemiologic associations with nuclear, cortical, and posterior subcapsular cataracts. Am J Epidemiol 1986 Dec;124(6):916-25.
Hirsch RP, Nadler MP, Miller D. Glare measurement as a predictor of outdoor vision among cataract patients. Ann Ophthalmol 1984a Oct;16(10):965-8.
Hirsch RP, Nadler MP, Miller D. Clinical performance of a disability glare tester. Arch Ophthalmol 1984b Nov;102(11):1633-6.
Holahan J, Berenson RA, Kachavos PG. Area variations in selected Medicare procedures. Health Aff (Millwood) 1990 Winter;9(4):166-75.
Holladay JT, Prager TC, Trujillo J, Ruiz RS. Brightness acuity test and outdoor visual acuity in cataract patients. J Cataract Refract Surg 1987 Jan;13(1):67-9.
Hollands RH, Drance SM, Schulzer M. The effect of acetylcholine on early postoperative intraocular pressure. Am J Ophthalmol 1987 Jun 15;103(6):749-53.
Hollows F, Moran D. Cataract-the ultraviolet risk factor. Lancet 1981 Dec 5;2(8258):1249-50.
Howes SC, Caelli T, Mitchell P. Contrast sensitivity in diabetics with retinopathy and cataract. Aust J Ophthalmol 1982 Aug;10(3):173-8.
Hunt L. Caution: systemic adverse reactions from eye medications. Insight 1991 Aug;16(4):5.
Immonen I, Tuominen R, Raivo I. Visual results and social rehabilitation after cataract surgery: a retrospective comparison of the effect of non-IOL and IOL surgery. Acta Ophthalmol (Copenh) 1988;66:572-6.
Ing MR. Potential acuity meter to predict postoperative visual acuity. J Cataract Refract Surg 1986 Jan;12(1):34-5.
Irvine AR, Kratz RP, O'Donnell JJ. Endothelial damage with phacoemulsification. Arch Ophthalmol 1978 June;96:1023-6.
Isaac NE, Walker AM, Jick H, Gorman M. Exposure to phenothiazine drugs and risk of cataract. Arch Ophthalmol 1991 Feb;109(2):256-60.
Italian-American Cataract Study Group. Risk factors for age-related cortical, nuclear, and posterior subcapsular cataract. Am J Epidemiol 1991 Mar 15;133(6):541-53.
Jacques PF, Chylack LT Jr, McGandy RB, Hartz SC. Antioxidant status in persons with and without senile cataract. Arch Ophthalmol 1988 Mar;106(3):337-40.
Jacques PF, Hartz SC, Chylack LT Jr, McGandy RB, Sadowski JA. Nutritional status in persons with and without senile cataract: blood vitamin and mineral levels. Am J Clin Nutr 1988 Jul;48(1):152-8.
Jampel HD, Thompson JR, Baker CC, Stark WJ. A computerized analysis of astigmatism after cataract surgery. J Ophthalmic Nurs Technol 1987 May-Jun;6(3):100-5.
Javitt JC, McBean AM, Nicholson GA, Babish JD, Warren JL, Krakaver H. Undertreatment of glaucoma among black Americans. N Engl J Med 1991 Nov 14;325(20):1418-22.
Javitt JC, Tielsch JM, Canner JK, Kolb MM, Sommer A, Steinberg EP. National outcomes of cataract extraction: increased risk of retinal complications associated with Nd:YAG laser capsulotomy. Ophthalmology 1992 Oct;99(10):1487-98.
Kahn HA, Leibowitz HM, Ganley JP, Kini MM, Colton T, Nickerson RS, Dawber TR. The Framingham Eye Study. I. Outline and major prevalence findings. Am J Epidemiol 1977 Jul;106(1):17-32.
Kaplan EB, Boeckmann AJ, Roizen MF, Sheiner LB. Elimination of unnecessary preoperative laboratory tests. Anesthesiology 1982 Sep;57(3 Suppl):A445.
Kaplan EB, Sheiner LB, Boeckmann AJ, Rozien MF, Beal SL, Cohen SN, Nicoll CD. The usefulness of preoperative laboratory screening. JAMA 1985 Jun 28;253(24):3576-81.
Karhunen U, Orko R. Nausea and vomiting after local anesthesia for cataract extraction in elderly female patients - effect of droperidol premedication. Ophthalmic Surg 1981 Nov;12(11):810-2.
Kattan HM, Flynn HW Jr, Pflugfelder SC, Robertson C, Forster RK. Nosocomial endophthalmitis survey: current incidence of infection after intraocular surgery. Ophthalmology 1991 Feb;98(2):227-38.
Katzen LE, Fleischman JA, Trokel SL. The YAG laser: an American experience. J Am Intraocul Implant Soc 1983 Spring;9(2):151-6.
Kemp KB, Boardman B. Appropriate care for cataract surgery patients before and after surgery. Issues of medical safety and appropriateness. Washington: U.S. Congress, Office of Technology Assessment, Health Program; 1988 Oct.
Kennedy RH, Brubaker RF, O'Fallon WM, Melton LJ 3d. Impact on referral bias on evaluation of cataract surgery. Am J Ophthalmol 1985 Feb 15;99(2):149-53.
Kersten RC, Kolder HE. Intraocular lens implantation: residents vs. staff. Ophthalmic Surg 1982 Jun;13(6):470-4.
Kinoshita JH. A thirty year journey in the polyol pathway. Exp Eye Res 1990 Jun;50(6):567-73.
Kinoshita JH, Fukushi S, Kador P, Merola LO. Aldose reductase in diabetic complications of the eye. Metabolism 1979 Apr;28(4 Suppl 1):462-9.
Klein BE, Klein R, Moss SE. Prevalence of cataract in a population based study of persons with diabetes mellitus. Ophthalmology 1985 Sep;92(9):1191-6.
Knighton RW, Slomovic AR, Parrish RK 2d. Glare measurements before and after neodymium-YAG laser posterior capsulotomy. Am J Ophthalmol 1985 Nov;100(5):708-13.
Knolle GE Jr. Knife versus neodymium. YAG laser posterior capsulotomy: a one-year followup. J Am Intraocul Implant Soc 1985 Sep;11(5):448-55.
Koch DD. Glare and contrast sensitivity testing in cataract patients. J Cataract Refract Surg 1989 Mar;15(2):158-64.
Koch DD, Liu JF, Gill EP, Parke DW 2d. Axial myopia increases the risk of retinal complications after neodymium-YAG laser posterior capsulotomy. Arch Ophthalmol 1989 Jul;107(7):986-90.
Kolder HE. Care of cataracts. Prim Care 1982 Dec;9(4):801-15.
Komatsu M, Kanagami S, Shimizu K. Ultraviolet-absorbing intraocular lens versus non-UV-absorbing intraocular lens: camparison of angiographic cystoid macular edema. J Cataract Refract Surg 1989 Nov;15(6):654-7.
Kooner KS, Cooksey JC, Perry P, Zimmerman TJ. Intraocular pressure following ECCE, phacoemulsification, and PC-IOL implantation. Opthalmic Surg 1988 Sep;19(9):643-6.
Kooner KS, Dulaney DD, Zimmerman TJ. Intraocular pressure following extracapsular cataract extraction and posterior chamber intraocular lens implantation. Ophthalmic Surg 1988 Jul;19(7):471-4.
Kraff M, Sanders D. Planned extracapsular extraction vs. phacoemulsification with IOL implantation: a comparison of concurrent series. J Am Intraocul Implant Soc 1982;8:38-41.
Kraff MC, Sanders DR. Incidence of retinal detachment following posterior chamber intraocular lens surgery. J Cataract Refract Surg 1990 Jul;16(4):477-80.
Kraff M, Sanders D, Jampol L. Prophylaxis of pseudophakic cystoid macular edema with topical indomethacin. Ophthalmology 1982 Aug;89(8):885-90.
Kraff MC, Sanders DR, Jampol LM, Lieberman HL. Effect of primary capsulotomy with extracapsular surgery on the incidence of pseudophakic cystoid macular edema. Am J Ophthalmol 1984 Aug 15;98(2):166-70.
Kraff MC, Sanders DR, Jampol LM, Lieberman HL. Effect of an ultraviolet-filtering intraocular lens on cystoid macular edema. Ophthalmology 1985 Mar;92(3):366-9.
Kraff MC, Sanders DR, Lieberman HL. Specular microscopy in cataract and intraocular lens patients. A report of 564 cases. Arch Ophthalmol 1980 Oct;98(10):1782-4.
Kraff M, Sanders D, Lieberman H. The results of posterior chamber lens implantation. J Am Intraocul Implant Soc 1983 Spring;9(2):148-50.
Kraff MC, Sanders DR, Lieberman HL. Intraocular pressure and the corneal endothelium after neodymium-YAG laser posterior capsulotomy. Relative effects of aphakia and pseudophakia. Arch Ophthalmol 1985 Apr;103(4):511-4.
Kratz R, Mazzocco T, Davidson B. The consecutive implantation of 250 Shearing intraocular lenses. Contact Intraocul Lens Med J 1979;5:123.
Kratz R, Mazzocco TR, Davidson B, Colvard DM. The Shearing intraocular lens: a report of 1000 cases. J Am Intraocul Implant Soc 1981a Jan;7(1):55-7.
Kratz RP, Mazzocco TR, Davidson B, Colvard DM. A comparative analysis of anterior chamber, iris-supported, capsule-fixated, and posterior chamber intraocular lenses following cataract extraction by phacoemulsification. Ophthalmology 1981b Jan;88(1):56-8.
Kupfer C. The conquest of cataract: a global challenge. Trans Ophthalmol Soc U K 1984;104(Pt 1):1-10.
Lachs MS, Feinstein AR, Cooney LM Jr, Drickamer MA, Marottoli RA, Pannill FC, Tinetti ME. A simple procedure for general screening for functional disability in elderly patients. Ann Intern Med 1990 May 1;112(9):699-706.
Lawrence VA, Gafni A, Gross M. The unproven utility of the preoperative urinalysis: economic evaluation. J Clin Epidemiol 1989;42(12):1185-92.
Laws DE, Watts MT, Kirby GR, Lawson J. Is padding necessary after cataract extraction? Br J Ophthalmol 1989 Sep;73(9):699-701.
Leader S. (Public Policy Institute, Washington). The outpatient surgical experiences of aged Medicare enrollees. Washington: American Association of Retired Persons; 1990 Aug.
Leaming DV. Practice styles and preferences of ASCRS members-1987 survey. J Cataract Refract Surg 1988 Sept;14(5):552-9.
Leaming DV. Attitudes toward advertising among Fellows of the American Academy of Ophthalmology: 1988. CLAO J 1990 Apr-Jun;16(2):144-50.
Leff SR, Welch JC, Tasman W. Rhegmatogenous retinal detachment after YAG laser posterior capsulotomy. Ophthalmology 1987 Oct;94(10):1222-5.
Lempert P, Hopcroft M, Lempert Y. Evaluation of posterior subcapsular cataracts: with spatial contrast acuity. Ophthalmology 1987 Aug;Pt 2:14-8.
Leske MC, Chylack LT Jr, Sperduto R, Khu P, Wu SY, McCarthy D. Lens Opacities Case-Control Study Group. Evaluation of a lens opacities classification system. Arch Ophthalmol 1988 Mar;106(3):327-9.
Leske MC, Chylack LT Jr, Wu SY. The lens opacities case-control study: risk factors for cataract. Arch Ophthalmol 1991 Feb;109(2):244-51.
Leske MC, Sperduto RD. The epidemiology of senile cataracts: a review. Am J Epidemiol 1983 Aug;118(2):152-65.
Levin ML. Opalescent nuclear cataract. J Cataract Refract Surg 1989 Sep;15(5):576-9.
Levy JH, Dodick JM. Initial clinical results with YAG laser capsulotomy with a monomode, Q-switched unit. J Am Intraocul Implant Soc 1984 Summer;10(3):341-2.
Levy JH, Pisacano AM. Comparison of techniques and clinical results of YAG laser capsulotomy with two Q-switched units. J Am Intraocul Implant Soc 1985 Mar;11(2):131-3.
Levy JH, Pisacano AM. Initial clinical studies with silicone intraocular implants. J Cataract Refract Surg 1988 May;14(3):294-8.
Lewis H, Singer TR, Hanscom TA, Straatsma BR. A prospective study of cystoid macular edema after neodymium:YAG laser posterior capsulotomy. Ophthalmology 1987 May;94(5):478-82.
Leys MJ, Pameijer JH, de Jong PT. Intermediate-term changes in intraocular pressure after neodymium-YAG laser posterior capsulotomy. Am J Ophthalmol 1985 Aug;100(2):332-3.
Lichtenstein SB. Cataracts 1986: facts versus myth. Trans Stud Coll Physicians Phila 1986 Mar;8(1):19-25.
Liesegang TJ, Bourne WM, Ilstrup DM. Secondary surgical and neodymium-YAG laser discissions. Am J Ophthalmol 1985 Oct;100(4):510-9.
Liesegang TJ, Bourne WM, Ilstrup DM. Prospective 5-year postoperative study of cataract extraction and lens implantation. Trans Am Ophthalmol Soc 1990;87:57-77.
Linn DK, Zimmerman TJ, Nardin GF, Yung R, Berberich S, DuBiner H, Fuqua M. Effects of intracameral carbachol on intraocular pressure after cataract extraction. Am J Ophthalmol 1989 Feb 15;107(2):133-6.
Lischwe TD, Ide CH. Predicting visual acuity after cataract surgery using the blue field entoptoscope and projected slides. Ophthalmology 1988 Feb;95(2):256-60.
Littlewood K, Constable I. Vitreous hemorrhage after cataract extraction. Br J Ophthalmol 1985 Oct;14(4):696-9.
Loh RC, Chew KL, Phua RC, Tong NH. Intraocular lens implantation: a full circle. Ann Acad Med Singapore 1985 Oct;14(4):696-9.
Low CR. Outpatient cataract surgery. AORN J 1978 Jul;28(1):35-40.
MacEwen CJ, Baines PS. Retinal detachment following YAG laser capsulotomy. Eye 1989;3(Pt 6):759-63.
Magno BV, Datiles MB 3d, Sperduto R, Podgor M, Lasa MSM, Lee J. Cataract progression rate using Lens Opacity Classification System II. Invest Ophthalmol Vis Sci 1991 Mar;32(4 Suppl):1244.
Maltzman BA, Cinotti AA, Calderone JP. Preadmission evaluation and elective cataract surgery. J Med Soc NJ 1981 Jul;78(7):519-20.
Maltzman BA, Cinotti DJ, Horan CA, Rengel AM. Posterior chamber implants and post-operative refractive astigmatism. CLAO J 1983 Jul-Sep;9(3):229-31.
Maltzman BA, Haupt E, Cucci P. Effect of the laser ridge on posterior capsule opacification. J Cataract Refract Surg 1989 Nov;15(6):644-6.
Maltzman BA, Haupt E, Notis C. Relationship between age and time of cataract extraction and time interval before capsulotomy for opacification. Ophthalmic Surg 1989 May;20(5):321-4.
Maltzman BA, Horan C, Rengel A. Penlight test for glare disability of cataracts. Ophthalmic Surg 1988 May;19(5):356-8.
Markoff J, Levin AJ, Behar R. Uncomplicated bilateral intraocular lens implants: intracapsular and extracapsular results in the same patient. Trans Ophthalmol Soc U K 1985;104(Pt 3):270-2.
Maruszczak D, Jensen H, Goldschmidt E. Preserile cataract. A followup investigation with special reference to occupational aspects. Acta Ophthalmol (Copenh) 1979 Oct;57(5):800-11.
Masket S. Astigmatic analysis of the scleral pocket incision and closure. CLAO J 1985 Jul-Sep;11(3):206-9.
Masket S, editor. Uncomplicated extracapsular cataract extraction. J Cataract Refract Surg 1988 Nov;14(6):679-84.
Masket S. Reversal of glare disability after cataract surgery. J Cataract Refract Surg 1989 Mar;15(3):165-8.
Masket S. Comparison of the effect of topical corticosteroids and nonsteroidals on postoperative corneal astigmatism. J Cataract Refract Surg 1990 Nov;16(6):715-8.
Maudgal PC, Stout RW, vanBalen AT. VCTS chart evaluation as a screening test. Doc Ophthalmol 1988 Aug;69(4):399-405.
Maynor R. Lens-induced complications with anterior chamber lens implants. J Am Intraocul Implant Soc 1983 Spring;9(2):450-2.
McCaffrey M, Lusby F. A review of 584 3M style 30 intraocular lens implants. J Cataract Refract Surg 1986 May;12:278-80.
McMahan LB. Anticoagulants and cataract surgery. J Cataract Refract Surg 1988 Sep;14(5):569-71.
Mele L, Alston C, Moorman C, Wang F, Fozard J, Taylor HR, West SK. Cataracts and cardiovascular disease. Invest Ophthalmol Vis Sci 1990 Mar;31(4 Suppl):236.
Menapace R, Skorpik C, Wedrich A. Evaluation of 150 consecutive cases of poly HEMA posterior chamber lenses implanted in the bag using a small-incision technique. J Cataract Refract Surg 1990 Sep;16(5):567-77.
Meyers EF. Problems during eye surgery. Under local anesthesia, is standby necessary? Anesth Rev 1979 Jul;6(7):23-5.
Migliori ME, Beckman H, Channell MM. Intraocular pressure changes after neodymium-YAG laser capsulotomy in eyes pretreated with timolol. Arch Ophthalmol 1987 Apr;105(4):473-5.
Milauskas AT. Posterior capsule opacification after silicone lens implantation and its management. J Cataract Refract Surg 1987 Nov;13(6):644-8.
Milauskas AT. Capsular bag fixation of one-piece silicone lenses. J Cataract Refract Surg 1990 Sep;16(5):583-6.
Miller ST, Graney MJ, Elam JT, Applegate WB, Freeman JM. Predictions of outcomes from cataract surgery in elderly persons. Ophthalmology 1988 Aug;95(8):1125-9.
Minassian DC, Mehra V, Jones BR. Dehydrational crisis from severe diarrhea or heatstroke and risk of cataract. Lancet 1984 Apr 7;1(8380):751-3.
Minkowski JS, Palese M, Guyton DL. Potential acuity meter using a minute serial pinhole aperture. Ophthalmology 1983 Nov;90(11):1360-8.
Miris R, Missotten LS. Evaluation of the macular function in cataractous eyes by means of the blue field entoptoscope. Bull Soc Belge Ophthalmol 1982;201:121-6.
Mizuno K, Miyake K. Pre- and postoperative therapy in cataract extraction. Ophthalmic Surg 1987 Feb;18(2):143-52.
Mohan M, Sperduto RD, Angra SK, Milton RC, Mathur RL, Underwood BA, Jaffery N, Pandya CB, Chhabra VK, Vajpayee RB. India-US case-control study of age-related cataracts. India-US Case-Control Study Group [Erratum. In: Arch Ophthalmol 1989 Sep;107(9):1288]. Arch Ophthalmol 1989 May;107(5):670-6. Comment. In: Arch Ophthalmol 1990 Jan;108(1):13-4.
Moisseiev J, Bartov E, Schochat A, Blumenthal M. Long-term study of the prevalence of capsular opacification following cataract surgery. J Cataract Refract Surg 1989 Sep;15(5):531-3.
Morris M, Klett Z, Gieser SC, Couch JM, Hirsch J. Assessment of potential contrast sensitivity. Part I: Preoperative prediction of contrast sensitivity following intraocular lens implantation. J Cataract Refract Surg 1991 Jan;17:37-44.
Moschos M. Extracapsular extraction and anterior chamber flexible lens implantation. Ann Ophthalmol 1988 Dec;20(12):478-9, 482.
Munoz B, West S, Tajchman U, Bochow T. Alcohol intake and risk of posterior subcapsular cataract. Arch Ophthalmol. Forthcoming.
Munoz B, West S, Wang F, Taylor HR. Measuring cataract progression for longitudinal studies. Invest Ophthalmol Vis Sci 1991 Mar;32(4 Suppl):1243.
Murphy GE. Limitations of blue field entoptoscopy in evaluating macular function. Ophthalmic Surg 1983 Dec;14(12):1033-6.
Naeser K, Nielsen NE, Hansen TE. Morphological changes 2 1/2 years after extracapsular cataract extraction with implantation of a posterior chamber lens. A prospective re-examination. Acta Ophthalmol (Copenh) 1990 Jun;68(3):259-64.
Naeser K, Rask KL, Hansen TE. Complications and visual outcome 4 months after extracapsular cataract extraction with implantation of posterior chamber lenses. A prospective clinical study. Acta Ophthalmol (Copenh) 1986a Oct;64(5):540-3.
Naeser K, Rask KL, Hansen TE. Morphological changes after extracapsular cataract extraction with implantation of posterior chamber lenses. A prospective clinical study. Acta Ophthalmol (Copenh) 1986b Jun;64(6):323-9.
National Cholesterol Education Program. Report of the Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults. Washington: Department of Health and Human Services (US); 1988.
National Institutes of Health. Consensus Development Conference Statement: Geriatric assessment methods for clinical decision-making. J Am Geriatr Soc 1988 Apr;36(4):342-7.
Naylor G, Sutton GA. Gonioscopic findings following insertion of Pearce Lasagap and Nova Curve Kratz posterior chamber intraocular lenses in extracapsular cataract extraction. Ophthalmic Surg 1989 Sep;20(9):638-42.
Naylor G, Sutton GA, Morrell AJ, Kearce JL. Intercapsular versus extracapsular cataract extraction. Ophthalmic Surg 1989 Nov;20(11):766-8.
Neuhaus RW, Straatsma BR. Cataract surgery with intraocular lens implantation by ophthalmology resident surgeons. Ophthalmic Surg 1983 Mar;14(5):415-7.
Neumann AC, Cobb B. Advantages and limitations of current soft intraocular lenses. J Cataract Refract Surg 1989 May;15(3):257-63.
Neumann AC, McCarty GR, Locke J, Cobb B. Glare disability devices for cataractous eyes: a consumer's guide. J Cataract Refract Surg 1988 Mar;14(2):212-6.
Neumann AC, McCarty GR, Sanders DR, Roanan MG. Small incisions to control astigmatism during cataract surgery. J Cataract Refract Surg 1989 Jan;15:78-84.
Neumann AC, McCarty GR, Steedle TO, Sanders DR, Raanan MG. The relationship between indoor and outdoor Snellen visual acuity in cataract patients. J Cataract Refract Surg 1988a Jan;14(1):35-9.
Neumann AC, McCarty GR, Steedle TO, Sanders DR, Raanan MG. The relationship between cataract type and glare disability as measured by the Miller-Nadler glare tester. J Cataract Refract Surg 1988b Jan;14(1):40-5.
Newcomb RD, Potter JW. Diagnostic outcomes of optometric referrals in a VA medical center. J Am Optom Assoc 1979 Aug;50(8):881-7.
1988 Joint National Committee. The 1988 Report of the Joint National Committee on detection, evaluation, and treatment of high blood pressure. Arch Intern Med 1988 May;148(5):1023-38.
Nirankari VS, Richards RD. Complications associated with the use of the neodymium:YAG laser. Ophthalmology 1985 Oct;92(10):1371-5.
Nishi O. Incidence of posterior capsule opacification in eyes with and without posterior chamber intraocular lenses. J Cataract Refract Surg 1986 Aug;12(8):519-22.
Noble BA, Hayward JM, Huber C. Secondary evaluation of hydrogel lens implants. Eye 1990;4(Pt 3):450-5.
Ober RR, Wilkinson CP, Fiore JV Jr, Maggiano JM. Rhegmatogenous retinal detachment after neodymium-YAG laser capsulotomy in phakic and pseudophakic eyes. Am J Ophthalmol 1986 Jan 15;101(1):81-9.
O'Donnell FE, Santos BA. Posterior capsular-zonular disruption in planned extracapsular surgery. Arch Ophthalmol 1985 May;103(5):652-3.
O'Donnell FE Jr, Santos BA. Prospective study of posterior capsule-zonular disruption during extracapsular cataract extraction: eliminating iatrogenic disruption. J Cataract Refract Surg 1990 May;16(3):329-32.
O'Malley TP Jr, Newmark TS, Rothman MI, Strassman HD. Emotional aspects of cataract surgery. Int J Psychiatry Med 1989;19(1):85-9.
Oxford Cataract Treatment and Evaluation Team (OCTET). Subjective assessment of the effect of cataract surgery and a review of long term aims. Eye 1987;1:247-53.
Pallin SL. Comparison of induced astigmatism with phacoemulsification and extracapsular cataract extraction [Erratum. In: J Cataract Refract Surg 1987 Jul;13(4):461]. J Cataract Refract Surg 1987 May;13(3):274-8.
Parker WT, Clorfeine GS. Long-term evolution of astigmatism following planned extracapsular cataract extraction. Arch Ophthalmol 1989 May;107(3):353-7.
Pedersen OO. Phacoemulsification and intraocular lens implantation in patients with cataract. Experiences of a beginning phacoemulsification surgeon. Acta Ophthalmol (Copenh) 1990 Feb;68(1):59-64.
Percival SPB. Capsular bag implantation of the hydrogel lens. J Cataract Refract Surg 1987a Nov;13(6):627-9.
Percival SPB. Early experience with soft hydrogel implants. Eye 1987b;1:735-7.
Peto R, Gray R, Collins R, Wheatley K, Henekens C, Jamrozik K, Warlow C, Hafner B, Thompson E, Norton S, et al. Randomized trial of prophylactic daily aspirin in British male doctors. BMJ 1988 Jan 30;296(6618):313-6.
Peyman GA, Caldwell DR, Conway MD, Viherkosky E, Wechstrom K. Early clinical experience with a new generation Q-switched neodymium:YAG laser. J Am Intraocul Implant Soc 1985 May;11(3):292-4.
Podgor MJ, Cassel GH, Kannel WB. Lens changes and survival in a population-based study. N Engl J Med 1985 Dec 5;313(23):1438-44.
Podgor MJ, Leske MC, Ederer F. Incidence estimates for lens changes, macular changes, open angle glaucoma and diabetic retinopathy. Am J Epidemiol 1983 Aug;118(2):206-12.
Pollack JP, Brown RH, Crandall AS, Robin AL, Stewart RH, White GL. Prevention of the rise in intraocular pressure following Neodymium-YAG posterior capsulotomy using topical 1% apraclonidine. Arch Ophthalmol 1988 Jun;106(6):754-7.
Pollack JP, Brown RH, Crandall AS, Robin AL, Stewart RH, White GL. Effectiveness of apraclonidine in preventing the rise in intraocular pressure after neodymium:YAG posterior capsulotomy. Trans Am Ophthalmol Soc 1989;86:461-9.
Prager TC, Urso RG, Holladay JT, Stewart RH. Glare testing in cataract patients: instrument evaluation and identification of sources of methodological error. J Cataract Refract Surg 1989 Mar;15(2):149-57.
President's Commission for the Study of Ethical Problems in Medicine and Biomedical and Behavioral Research.Securing access to health care. Vol. I. Washington: Government Printing Office (US); 1983.
Preventive Services Task Force (US). Guide to preventive clinical services: an assessment of the effectiveness of 169 interventions. Baltimore: Williams and Wilkins; 1989. Chapter 32, Screening for glaucoma. p. 187-92.
Quigley HA. Mortality associated with ophthalmic surgery: a 20-year experience at the Wilmer Institute. Am J Ophthalmol 1974 Apr;77(4):517-24.
Raines M, Corridan P, O'Neill E. Posterior synechiae in intercapsular cataract surgery. Ophthalmic Surg 1989 Apr;20:245-9.
Rao GN, Aquavella JV, Goldberg SH, Berk SL. Pseudophakic bullous keratopathy. Relationship to preoperative corneal endothelial status. Ophthalmology 1984 Oct;91(10):1135-40.
Redmond RM, Dallas NL. Extracapsular cataract extraction under local anaesthesia without retrobulbar injection. Br J Ophthalmol 1990 Apr;74(4):203-4.
Revicki DA, Brown RE, Adler MA. Outcomes of cataract surgery with co-managed postoperative care. Report to the American Optometric Association. Washington: Battelle Human Affairs Research Centers; 1990 Jan. Report No. BHARC-013/89/060.
Rich W. The economics of Nd:YAG laser treatment. Dev Ophthalmol 1987;14:93-6.
Rich WJ, Condon PI, Percival SPB. Hydrogel intraocular lens experience with endocapsular implantation. Eye 1988;2:523-8.
Richter CU, Arzeno G, Pappas HR, Steinert RF, Puliafito C, Epstein DL. Intraocular pressure elevation following Nd:YAG laser posterior capsulotomy. Ophthalmology 1985a May;92(5):636-40.
Richter CU, Arzeno G, Pappas HR, Arrigg CA, Wasson P, Steinert RF. Prevention of intraocular pressure elevation following neodymium:YAG laser posterior capsulotomy. Arch Ophthalmol 1985b Jul;103(7):912-5.
Rickman-Barger L, Florine CW, Larson RS, Lindstrom RL. Retinal detachment after neodymium:YAG laser posterior capsulotomy. Am J Ophthalmol 1989 May 15;107(5):531-6.
Ridgway AE. Discussion of factors responsible for retinal detachments and other late complications after intraocular lens implantation. Trans Ophthalmol Soc U K 1985;104:539-40.
Roberts CJ, Fowkes FG, Ennis WP, Mitchell M. Possible impact of audit on chest x-ray requests from surgical wards. Lancet 1983 Aug 20;2(8347):446-8.
Roberts NK, Zalta E. Quality and cost-efficiency: the evidence for channeling. Qual Assur Util Rev 1988 Nov;3(4):120-3.
Roizen MF. The compelling rationale for less pre-operative testing. Can J Anaesth 1988;35(3 Pt 1):214-8.
Rucker L, Frye EB, Staten MA. Usefulness of screening chest roentgenograms in preoperative patients. JAMA 1983 Dec 16;250(23):3209-11.
Ruiz RS, Wilson CA, Musgrove KH, Prager TC. Management of increased intraocular pressure after cataract extraction. Am J Ophthalmol 1987 Apr;103(4):487-91.
Sanders DR, Kraff M. Steroidal and nonsteroidal anti-inflammatory agents. Effects on postsurgical inflammation and blood-aqueous humor barrier breakdown. Arch Ophthalmol 1984 Oct;102(10):1453-6.
Schanzer MC, Wilhelmus KR. Outpatient cataract surgery by ophthalmology residents in a county hospital. Ann Ophthalmol 1985 Aug;17(8):480-2.
Schubert HD. Vitreoretinal changes associated with rise in intraocular pressure after Nd:YAG capsulotomy. Ophthalmic Surg 1987 Jan;18(1):19-22.
Seddon JM, Christen WG, Manson JE, Buring JE, Sperduto RD, Hennekens CH. Low-dose aspirin and risks of cataract in a randomized trial of US physicians. Arch Ophthalmol 1991 Feb;109(2):252-5.
Seigel D, Sperduto RD, Ferres FL 3d. Aspirin and cataracts. Ophthalmology 1982 Apr;89(4):47A-49A.
Sellman TR, Lindstrom RL. Effect of a plano-convex posterior chamber lens on capsular opacification from Elschnig pearl formation. J Cataract Refract Surg 1988 Jan;14(1):68-72.
Severin TD, Severin SL. A clinical evaluation of the potential acuity meter in 210 cases. Ann Ophthalmol 1988a Oct;20(10):373-5.
Severin T, Severin S. Pseudophakic cystoid macular edema: a revised comparison of the incidence with intracapsular and extracapsular cataract extraction. Ophthalmic Surg 1988b Feb;19(2):116-8.
Shah GR, Gills JP, Durham DG, Ausmus WH. Three thousand YAG lasers in posterior capsulotomies: an analysis of complications and comparison to polishing and surgical discission. Ophthalmic Surg 1986 Aug;17(8):473-7.
Sheets JH. A step beyond ECCE. CLAO J 1987 Jan-Feb;13(1):67-70.
Shepherd JR. Induced astigmatism in small incision cataract surgery. J Cataract Refract Surg 1989a Jan;15(1):85-8.
Shepherd JR. Capsular opacification associated with silicone implants. J Cataract Refract Surg 1989b Jul;15(4):448-50.
Shimizu H. Intraoperative and postoperative complications with a posterior chamber lens. J Cataract Refract Surg 1988 May;14(3):281-5.
Silverstone DE, Novack GD, Kelley EP, Chen KS. Prophylactic treatment of intraocular pressure elevations after neodymium:YAG laser posterior capsulotomies and extracapsular cataract extractions with levobunolol. Ophthalmology 1988 Jun;95(6):713-8.
Silvestri G, Shepherd WF, Johnston PB. Pseudophakic retinal detachments and post-operative visual acuity. Int Ophthalmol 1989 Sep;13(5):345-9.
Simcoe CW. Simcoe posterior chamber lens: theory, techniques and results. J Am Intraocul Implant Soc 1981 Apr;7(2):154-7.
Simel PJ. Posterior chamber implants without iridectomy. J Am Intraocul Implant Soc 1982 Spring;8(2):141-3.
Sinclair SH, Loebl M, Riva CE. Blue field entopic phenomenon in cataract patients. Arch Ophthalmol 1979 Jun;9(6)7:1092-5.
Singh H, Cooper RL, Alder VA, Crawford GJ, Terrell A, Constable IJ. The Arden grating acuity: effect of age and optical factors in the normal patient, with prediction of the false negative rate in screening for glaucoma. Br J Ophthalmol 1981 Aug;65(8):518-24.
Skalka HW. Arden grating test in evaluating "early" posterior subcapsular cataracts. South Med J 1981a Nov;74(11):1368-70.
Skalka HW. Blue field entoptoscopy and VER in preoperative cataract evaluation. Ophthalmic Surg 1981b Sep;12(9):642-5.
Slomovic AR, Parrish RK 2d. Acute elevations of intraocular pressure following Nd:YAG laser posterior capsulotomy. Ophthalmology 1985 Jul;92(7):973-6.
Slomovic AR, Parrish RK 2d, Forster RK, Cubillas A. Neodymium-YAG laser posterior capsulotomy. Central corneal endothelial cell density. Arch Ophthalmol 1986 Apr;104(4):536-8.
Smith PW, Stark WJ, Maumenee AE, Michels RG, Glaser BM, Bonham RD. Retinal detachment after extracapsular cataract extraction with posterior chamber intraocular lens. Ophthalmology 1987 May;94(5):495-504.
Smith R. Cataract extraction without retrobulbar anaesthetic injection. Br J Ophthalmol 1990 Apr;74(4):205-7.
Smith SJ, Drance SM. Difficulties patients have at home after cataract surgery. Can J Ophthalmol 1984;19:6-9.
Sommer A, Tielsch JM, Katz J, Quigley H, Gottsch JD, Javitt JC, Martone JF, Royall RM, Whitt KA, Ezrine S. Racial differences in the cause-specific prevalence of blindness in East Baltimore. N Engl J Med 1991 Nov 14;325(20):1412-7.
Southwick PC, Olson RJ. Shearing posterior chamber intraocular lens. Five-year postoperative results. Am Intraocul Implant Soc J 1984 Summer;10(3):318-23.
Sperduto RD, Hiller R. The prevalence of nuclear, cortical, and posterior subcapsular lens opacities in a general population sample. Ophthalmology 1984 Jul;91(7):815-8.
Sperduto RD, Seigel D. Senile lens and senile macular changes in a population-based sample. Am J Ophthalmol 1980 Jan;90(1):86-91.
Spurny RC, Zaldivar R, Belcher CD 3d, Simmons RJ. Instruments for predicting visual acuity. Arch Ophthalmol 1986 Feb;104(2):196-200.
Stark WJ Jr, Maumenee AE, Datiles M, Fagadav W, Baker CC, Worthen D, Auer C, Klein P, McGhee E, Jacobs MC, et al. Intraocular lenses: complications and visual results. Trans Am Ophthalmol Soc 1983;81:280-309.
Stark WJ, Worthen D, Holladay JT, Murray G. Neodymium:YAG lasers. An FDA report. Ophthalmology 1985 Feb;92(2):209-12.
Steinert RF, Brint SF, White SM, Fine IH. Astigmatism after small incision cataract surgery: a prospective, randomized, multicenter comparison of 4- and 6.5 mm incisions. Ophthalmology 1991;98(4):417-24.
Steinert RF, Puliafito CA, Kumar SR, Dudak SD, Patel S. Cystoid macular edema, retinal detachment and glaucoma after Nd:YAG laser posterior capsulotomy. Am J Ophthalmol 1991 Oct;112(4):373-80.
Stephenson SV. Ambulatory surgical centers. JAMA 1985 Jan 18;253(3):242-3.
Sterling S, Wood TO. Effect of intraocular lens convexity on posterior capsule. J Cataract Refract Surg 1986 Nov;12(6):655-7.
Stern AL, Taylor DM, Bernstein R. Neodymium-YAG laser and cataract surgery. Conn Med 1985 Oct;49(10):641-2.
Stilma JS, Boen-Tan TN. Timolol and intra-ocular pressure elevation following neodymium:YAG laser surgery. Doc Ophthalmol 1986 Jan 15;61(3-4):233-9.
Stone LS, Kline OR Jr, Sklar CA. Intraocular lenses and anticoagulation and antiplatelet therapy. J Am Intraocul Implant Soc 1985 Mar;11(2):165-8.
Story PG. Intraocular lenses with posterior convex optics: a clinical review. Ophthalmic Surg 1988 Sep;19(9):658-61.
Straatsma BR, Meyer KT, Bastek JV, Lightfoot DO. Posterior chamber intraocular lens implantation by ophthalmology residents. A prospective study of cataract surgery. Ophthalmology 1983 Apr;90(4):327-35.
Stur M. Long-term changes of the corneal endothelium following intracapsular cataract extraction with implantation of open loop anterior chamber lenses. Acta Ophthalmol (Copenh) 1988 Dec;66:678-86.
Stur M, Grabner G, Dorda W. Changes of the corneal endothelium following intracapsular cataract extraction with implantation of semiflexible anterior chamber lenses. I. Results of the early post-operative period. Acta Ophthalmol (Copenh) 1984 Aug;62(4):586-94.
Sudhakar J, Ravindran RD, Natchiar G. Analysis or complications in 1000 cases of posterior chamber intra ocular lens implantation. Indian J Ophthalmol 1989 Apr-Jun;37(2):78-9.
Sutton GA. Intraocular lens implantation by surgeons in training. Br J Ophthalmol 1980 Sep;64(9):687-8.
Tabbut SE, Lindstrom RL. Laser retinometry versus clinical estimation of media: a comparison of efficacy in predicting visual acuity in patients with lens opacities. J Cataract Refract Surg 1986 Mar;12(2):140-5.
Taylor DM, Sachs SW, Stern AL. Aphakic cystoid macular edema. Longterm clinical observations. Surv Ophthalmol 1984 May;28 (Suppl):437-41.
Taylor HR. The environment and the lens. Br J Ophthalmol 1980 May;64(5):303-10.
Taylor HR, Sommer A. Cataract surgery: a global perspective. Arch Ophthalmol 1990 Jun;108(6):797-8.
Taylor HR, West SK, Rosenthal FS, Munoz B, Newland HS, Abbey H, Emmett EA. Effect of ultraviolet radiation on cataract formation. N Engl J Med 1988 Dec 1;319(22):1429-33. Comment. In: N Engl J Med 1989 May 11;320(19):1285-6.
Tomoda T, Tuberville AW, Wood TO. Timolol and postoperative intraocular pressure. J Am Intraocul Implant Soc 1984 Spring;101:180-1.
Tugwell P, Bombardier C, Buchanan WW, Goldsmith CH, Grace E, Hanna B. The MACTAR patient preference disability questionnaire—an individualized functional priority approach for assessing improvement in physical disability in clinical trials in rheumatoid arthritis. J Rheumatol 1987 Jun;14(3):446-51.
van Heyningen R, Harding JJ. A case-control study of cataract in Oxfordshire: some risk factors. Br J Ophthalmol 1988 72:804-8.
van Lith GH, Hekkert-Wiebenga W. Cataract, pattern stimulation and visually evoked potentials. Doc Ophthalmol 1983 Feb 28;55(1-2):107-12.
Van Oye R, Budo C, Galand A, Foetz B, Goes F. Two-year postoperative results of Galand lens implantation. J Cataract Refract Surg 1986 Mar;12(2):135-9.
Vitale S, West SK, Hallfrisch J, Muller D, Singh VN. Plasma vitamin C, E, and beta-carotene levels and risk of cataract. Invest Ophthalmol Vis Sci 1991;Mar;32(4 Suppl):723.
Vrijland HR, van Lith GH. The value of preoperative electro-ophthalmological examination before cataract extraction. Doc Ophthalmol 1983 Feb 28;55(1-2):153-6.
Wasserman EL, Axt JC, Sheets JH. Neodymium:YAG laser posterior capsulotomy. J Am Intraocul Implant Soc 1985 May;11(3):245-8.
Watts J. Retrospective comparison of lens implant surgery and cataract surgery in a provincial unit. Br J Ophthalmol 1986 Jun;70(6):415-7.
Weinstein GW. Clinical aspects of the visually evoked potential. Trans Am Ophthalmol Soc 1977;75:627-73.
Weiss JF. Glare and mesopic vision before and after cataract surgery. J Cataract Refract Surg 1990 Jan;16(1):88-91.
Weiss JL, Deichman CB. A comparison of retrobulbar and periocular anesthesia for cataract surgery. Arch Ophthalmol 1989 Jan;107(1):96-8.
West SK. Who develops cataracts [editorial]? Arch Ophthalmol 1991 Feb;109(2):196-8.
West SK, Munoz B, Emmett EA, Taylor HR. Cigarette smoking and risk of nuclear cataracts. Arch Ophthalmol 1989 Aug;107(8):1166-9.
West SK, Munoz BE, Newland HS, Emmett EA, Taylor HR. Lack of evidence for aspirin use and prevention of cataracts. Arch Ophthalmol 1987 Sept;105(9):1229-31.
West SK, Rosenthal F, Newland HS, Taylor HR. Use of photographic techniques to grade nuclear cataracts. Invest Ophthalmol Vis Sci 1988 Jan;29(1):73-7.
Whitaker D, Deady J. Prediction of visual function behind cataract using displacement threshold hyperacuity. Ophthalmic Physiol Opt 1989 Jan;9(1):20-4.
Whitaker VB, Whitaker R. Cultural, ethnic, racial and religious factors: implications for ophthalmic nursing practice and research. Insight 1991 Jun;16(3):28-31.
Whitsett JC, Balyeat HD, McClure B. Comparison of one-injection-site peribulbar anesthesia and retrobulbar anesthesia. J Cataract Refract Surg 1990 Mar;16(2):243-5.
Whittpen JR, Rapoza P, Sternberg P, Kuwashima L, Saklad J, Arnall P. Respiratory arrest following retrobulbar anesthesia. Ophthalmology 1986 Jul;93(7):867-70.
Williams ME. Why screen for functional disability in elderly persons [editorial]? Ann Intern Med 1990 May;112(9):639-40.
Williamson DE. One thousand consecutive outpatient cataract extractions. Eye Ear Nose Throat Mon 1975 Feb;54(2):52,55-6,57-60.
Wong MY, Kline OR Jr. Wills eye hospital residents' intraocular lens experience. Ophthalmic Surg 1982 Nov;13(11):934-5.
Woodhams J, Maddox R, Hunkeler J, Bruhl D, Lester J, Key C, Knolle G, Sheets J. A review of 1147 cases of Sheets lens implantations. Am Intraocul Implant Soc J 1984 Spring;10:185-7.
Wright PL, Wilkinson CP, Balyeat HD, Popham J, Reinke M. Antiographic cystoid macular edema after posterior chamber lens implantation. Arch Ophthalmol 1988 Jun;106(6):740-4.
Young PW, Schwab L. Intraocular lens implantation in developing countries: an ophthalmic surgical dilemma. Ophthalmic Surg 1989 Apr;20(4):241-4.
Zibrak JD, O'Donnell CR, Marton K. Indications for pulmonary function testing. Ann Intern Med 1990 May 15;112(10):763-71.