# Executive Summary

Functional impairment due to cataract in adults was designated as a topic for guideline development for two reasons. First, it is prevalent in the U.S. population, and, second, surgery for the condition is a significant item in the Medicare budget. It is the most common surgery performed on Americans age 65 and over, with an estimated 1.35 million procedures being performed every year at a cost of approximately $3.4 billion. Despite the fact that in the United States surgery is perceived as generally available, cataract remains an important cause of visual loss in the U.S. populations surveyed.

The panel chose to focus, in general, on functional impairment of the patient with cataract and, in particular, on improvement in function as a result of treatment for the condition. Functional impairment due to cataract in the adult is a broad topic. Although the word cataract immediately raises in most minds the question of surgery, the issues addressed in this guideline are much broader. From the perspective of the body's five senses, a cataract can cause a decrease in visual function that can be classed as a visual disability. The panel believes that it is important to recognize the impact of this disability on the individual's ability to function autonomously. Maintenance or restoration of autonomy through appropriate treatment to remove the disability, therefore, becomes the goal of the guideline.

The direct link between vision, independence, and quality of life makes vision one of our most precious attributes. Improving vision for the elderly with the skills of professional providers not only is possible but also should be a high priority.

This guideline is based, first, on knowledge derived from the relevant literature and, second, on expert opinion. The process of developing the guideline involved several stages. The panel defined the scope of the guideline and the topics to be researched and initiated a systematic review of the medical literature relating to cataract. The National Library of Medicine conducted a broad-based search of the available literature, and the literature review teams synthesized the findings in this literature in a series of scientific reports that were used in developing the guideline. Other inputs into the guideline included the panel's own expertise, information from open forum presentations, peer- and pilot-review results, and informal communications with the panel chair and panel members. In the absence of empirical evidence, the panel made informed judgments and agreed on them by consensus.

The guideline consists of recommendations for the provision of the highest quality of care for patients with functional impairment due to cataract, consistent with present knowledge, together with the panel's reasoning to support these recommendations.

To facilitate a broad approach to the care of persons with functional impairment due to cataract, this guideline covers the following subjects:

- Ethical issues, which are an integral component of the delivery of health care. When guidelines are developed, they must embody the covenantal motivation; no legislative enactment or legal contract can suffice. The covenant includes numerous elements that define the role and responsibility of the caregiver.

- The natural history of cataract and functional impairment due to cataract, risk factors for cataract, which provide the basis for our understanding of the disease and its impact on the patient, and the interventions that eventually might be undertaken to prevent the formation of cataract or reduce the disability caused by it. Currently, there is no medical treatment to prevent formation and progress of cataract in the otherwise healthy adult eye. The major risk factors for cataract are ultraviolet-B radiation, certain drugs, diabetes, smoking, and alcohol. There may also be an association with severe diarrhea or low antioxidant vitamin status. At this time, however, guidelines for risk factor management cannot be provided.

- Referral pathways and access to care. It is of great importance how patients with functional impairments due to cataract come to receive care and how this process of interaction with the health care system influences the outcome for the individual. The process of caring for a patient with functional impairment due to cataract should start when a visual disability is recognized. This should lead finally to consultation with an appropriate surgeon to make or confirm a diagnosis and provide appropriate treatment.

- Setting and providers of care. Major changes that have taken place in the setting of care in the past few years and how these new settings are structured can also have a crucial impact on the outcome. The setting for surgery should be where a patient can receive quality care in a safe environment, ideally close to his or her home or support system. This may mean that a surgeon other than the one who diagnosed the cataract performs the surgery, if it is in the patient's best interest. In addition, other health care providers (e.g., optometrists, anesthesia providers, home health nurses, social workers) are currently more visibly involved in certain components of the care of these patients as part of the health care team.

- The value and suitability of a series of preoperative tests used for a variety of purposes in the management of the patient with cataract. The decision to perform cataract surgery is generally made by judging the effect of the cataract on the patient's visual and overall function and assessing the patient's visual needs, after a thorough consideration of the potential risks associated with surgery. Several specific preoperative tests are discussed.

- Various aspects of treatment, including nonsurgical management, surgical management, the indications for surgery that are to be used in defining the suitability of a patient for surgery, preoperative evaluation, anesthesia, surgical techniques and complications, and second eye surgery. Modern cataract surgery is safe and effective in restoring vision in patients with cataracts.

- Postoperative care, rehabilitation, and yttrium aluminum garnet (YAG) capsulotomy for posterior capsular opacification. The components of postoperative care include patient education, evaluation of the condition at discharge, and postoperative visits and examinations. Numerous factors are involved in successful rehabilitation, and these are discussed fully. Finally, the management of functional impairment due to posterior capsular opacification is described in a way similar to the management of functional impairment due to cataract. This includes consideration of diagnosis, indications and contraindications for surgery, preoperative evaluations, the surgical technique and complications, postoperative care, and benefits and harms. Opacification of the posterior capsule is a natural consequence of modern cataract surgery. Now, with the availability of the YAG laser, it is possible to perform laser capsulotomy as an outpatient surgical procedure after cataract surgery.