# Acknowledgments

The development of this guideline is the result of the efforts of many individuals. In addition to those who researched and wrote the reports of the literature review, the panel wishes to acknowledge with gratitude those who contributed their expertise, advice, and technical support.

Earl Steinberg, MD, MPP, consultant to the panel on methodology of the literature review, participated in the development and implementation of the literature search and advised the panel throughout the process. He also participated in the literature review. Kay Dickersin, PhD, Director of the Ad Hoc Literature Review Group, maintained oversight of the entire process and consulted with the panel chair and panel members regarding reviews of individual topics. She also participated in the literature review. Lea Gamble supervised the logistics of the literature review and the distribution of the multitude of abstracts and articles to the review teams.

Paul Dokeki, PhD; Albert Jonsen, PhD; Tom Leonard-Martin, PhD; Robert O'Gorman, PhD; Edmund Pelligrino, PhD; Robert Veatch, PhD; and Richard Zaner, PhD, read and commented on drafts from the Ethics section.

Lisa Herdelin (12/91-present) and Bridget Reilly, PhD (5/91-12/91) were responsible for the overall administration of the project at Vanderbilt University School of Medicine. Lisa Herdelin also contributed to the editing of the final drafts of the documents. Susan Bigham and Sandra Wilkinson prepared drafts and revisions and were responsible for maintaining secretarial assistance to the panel.

Susan Garratt wrote drafts of the Clinical Practice Guideline and copyedited the Guideline Report and its three other versions. Robert Friedman, MD, prepared drafts of the Quick Reference Guide. David Hadorn, MD, developed the algorithm. Gary Stephenson and Marcia Whitson wrote drafts of the Patient's Guide. Naomi Levy and Charlie Smith served as production editors for the Clinical Practice Guideline. Maggie Rutherford of the Center for Research Dissemination and Liaison, Agency for Health Care Policy and Research (AHCPR), served as the managing editor on all guideline products.

Assistance with referencing, proofreading, copying, and mailing was provided by Ursula Otto, Richard Robinson, Steve Head, and Regan Logan, MD, from the Department of Ophthalmology at Vanderbilt University School of Medicine, and the following Vanderbilt University students: Toeleah Johnson, Charles Breeden II, Guy VanDell, and Sepand Moshiri. Staff of the National Library of Medicine under the direction of Ione Auston, MLS, Reference Librarian in the Office of Health Services Research Information, were especially helpful in assisting with the design of the literature search and carrying out exhaustive literature searches of the various data bases.

Jean Slutsky and Larry Williams of the Forum for Quality and Effectiveness in Health Care, AHCPR, provided technical assistance.

Finally, heartfelt gratitude is due the families of the panel members for their patience and support during the 2 years this guideline was in the making.