# Panel Members

- Denis M. O'Day, MD, FACS,
- Chair
- George Weeks Hale Professor and Chair
- Department of Ophthalmology
- Vanderbilt University School of Medicine
- Nashville, Tennessee
- Ophthalmologist
- Anthony J. Adams, OD, PhD
- Dean
- School of Optometry
- University of California
- Berkeley, California
- Optometrist
- Edwin H. Cassem, MD, FACP
- Chief of Psychiatry
- Department of Psychiatry
- Massachusetts General Hospital
- Boston, Massachusetts
- Psychiatrist
- John V. Donlon, Jr., MD
- Acting Chairman
- Department of Anesthesiology
- Massachusetts Eye and Ear Infirmary
- Boston, Massachusetts
- Anesthesiologist
- Donald J. Doughman, MD, FACS
- Professor
- Department of Ophthalmology
- University of Minnesota Hospital and Clinic
- Minneapolis, Minnesota
- Ophthalmologist
- Dagmar B. Friedman, MPH, LICSW
- Consultant
- Vision Rehabilitation Services
- Massachusetts Eye and Ear Infirmary
- Beverly Farms, Massachusetts
- Medical Social Worker
- Catherine Glynn-Milley, RN, CRNO
- President
- Specialty Nursing Agency, Inc.
- Santa Clara, California
- Home Health Nurse
- Harry L. Knopf, MD
- Associate Professor of Clinical Ophthalmology
- Department of Ophthalmology and Visual Sciences
- Washington University School of Medicine
- St. Louis, Missouri
- Ophthalmologist
- Ernest L. Mazzaferri, MD, FACP
- Professor and Chairman
- Department of Internal Medicine
- Ohio State University College of Medicine
- Columbus, Ohio
- Internist
- Steven A. Obstbaum, MD
- Professor of Clinical Ophthalmology
- Cornell University Medical School
- Director
- Department of Ophthalmology
- Lenox Hill Hospital
- New York, New York
- Ophthalmologist
- Charles J. Pappas, OD
- Director of Optometric Services
- Bascom Palmer Eye Institute
- University of Miami School of Medicine
- Miami, Florida
- Optometrist
- Eva N. Skinner, RN
- Los Angeles, California
- Patient Representative
- Alfred Sommer, MD, MHS
- Dean
- The Johns Hopkins School of Hygiene and Public Health
- Baltimore, Maryland
- Ophthalmologist
- Arlo C. Terry, MD
- Associate Clinical Professor of Ophthalmology
- University of Texas
- San Antonio, Texas
- Ophthalmologist
- Linda A. Vader, RN, CRNO
- Certified Registered Nurse in Ophthalmology
- University of Michigan
- Kellogg Eye Center
- Ann Arbor, Michigan
- Nurse Manager
- James R. Weber, MD
- Assistant Clinical Professor
- Department of Family and Community Medicine
- University of Arkansas
- Jacksonville, Arkansas
- Family Physician
- Von Best Whitaker, PhD, RN, C
- Assistant Professor
- School of Nursing
- University of Texas Health Science Center
- San Antonio, Texas
- Nurse
- Ira G. Wong, MD
- Chief
- Department of Ophthalmology
- Kaiser Permanente Medical Center
- Assistant Clinical Professor
- University of California - San Francisco
- Redwood City, California
- Ophthalmologist