# Foreword

The development of opacities or cataracts in the lens of the eye is a normal consequence of aging and is common in persons age 60 and over. In time, the opacities may affect vision and ultimately impair quality of life. With the increased prevalence of cataract as the U.S. population ages, the care of patients with cataract has become a major component of health care delivered to all Americans. An estimated 1.35 million cataract surgeries are performed annually.

Despite major technological advances in microsurgical techniques, concerns have been raised about the appropriateness of surgery for patients with functional impairment due to cataract. There is also concern that other factors, such as race and economics, may influence access to care. For laser capsulotomy, sometimes performed after cataract surgery to treat posterior opacification, there may be a vast difference in rates of performance even between contiguous States. Such findings suggest a lack of agreement on appropriate indications for use of the procedure. This guideline is written in response to these and other uncertainties. It sets out an approach to the process of care for patients with cataract that is comprehensive, coherent, and yet flexible enough to apply to a broad range of patients who experience functional impairment as a result of the visual effects of the cataract.

This Clinical Practice Guideline was developed under the sponsorship of the Agency for Health Care Policy and Research (AHCPR) of the U.S. Department of Health and Human Services. To develop this guideline, AHCPR convened an interdisciplinary expert panel made up of ophthalmologists, nurses, optometrists, internists, a psychiatrist, an anesthesiologist, a generalist, a clinical social worker, and a patient representative. The panel first undertook an extensive and interdisciplinary review of the process of care for the patient. Second, the panel conducted a comprehensive review of the field to define the existing knowledge base and to evaluate critically the assumptions and common wisdom in the field. Third, the panel initiated a peer review of the guideline drafts and field review with intended users in clinical sites. Finally, comments from these reviews were assessed and used in the development of the final guideline.

This is the first edition of the Clinical Practice Guideline on Cataract in Adults: Management of Functional Impairment. The panel recognizes that issues surrounding the management of cataract are complex and controversial. A revised edition will be produced in 2 years to reflect new research findings and the experience with newer methods of management.

Cataract Management Guideline Panel