# Guideline: Posterior Capsular Opacification and YAG Capsulotomy

Opacification of the posterior capsule is a consequence of modern cataract surgery. As the opacification increases, the patient begins to notice a decrease in visual function that can lead to functional impairment. The approach to the management of functional impairment due to posterior capsular opacification (PCO) is similar to that of functional impairment due to cataract.

## Background

PCO is a natural consequence of modern cataract surgery, whether performed by the extracapsular technique or by phacoemulsification (PE). As a result of this opacification, there is a gradual degradation in visual function that ultimately can become symptomatic to the patient. In the past, an invasive procedure involving incising the capsule with a knife (i.e., discission) was necessary to remove the opacity. This procedure was sometimes performed at the time of the cataract surgery. Now, with the availability of the YAG laser, it is possible to perform laser capsulotomy as an outpatient procedure after cataract surgery. Although YAG capsulotomy is a commonly performed procedure (over 600,000 Medicare recipients in 1991), there are few rigorously documented data available on indications for performing this procedure, the rate of immediate and long-term complications, and outcome from the perspective of the patient's quality of life after YAG capsulotomy. There is also no information on the rate of occurrence of visually significant PCO and the appropriate timing and rates of performance of the procedure.

## Literature Review

### Methods

The purpose of the literature review was to identify and review those articles that contained information on PCO and YAG capsulotomy in relation to functional impairment due to cataract. (For a full description of the literature review process, see Appendix O in the Guideline Report.)

### Results

The results of the literature review are as follows and are summarized in Evidence Tables O-1 to O-5 in Appendix O in the Guideline Report.

The computer search identified 138 papers thought to be relevant to the topic. Three additional papers thought to be relevant to the topic were identified from a variety of sources, which brought the total article count to 141. Seventy-eight were selected for further review because the abstract of the article suggested a relevance to the subject. Of the 78 articles, 2 pairs were found to be duplicates; one of each pair was excluded, leaving a total of 76 articles. One other paper (Javitt, Tielsch, Canner et al., 1992), the product of a study by the Cataract Patient Outcomes Research Team (PORT), was accepted for review, making a total of 77 out of 142 papers. The basis for inclusion of Javitt, Tielsch, Canner et al. (1992) was the potential importance of the data despite the failure to meet inclusion criteria (i.e., unpublished manuscript). This paper was published subsequent to the review. A total of 65 articles were excluded. Of the 77 included articles, 2 pairs contained identical data (Durham and Gills [1985]/ Shah, Gills, Durham et al. [1986] and Pollack, Brown, Crandall et al. [1989]/ Pollack, Brown, Crandall et al. [1988]).

A review of the 77 papers showed that very few of the studies were designed to answer the questions the panel was asked to address, and most suffered from limitations common to retrospective studies or methodologic defects that severely constrained the conclusiveness of the results. These design and methodologic problems are discussed within the context of each question. In spite of these shortcomings, the reviewers felt that there was sufficient clinical information in these papers to allow for some conclusions and to provide a basis to stimulate future studies.

Since many of the studies provided information on more than one of the five questions addressed by the panel, the sum of the total number of studies for each question is greater than 77. A critical review of the available information on each question follows.

#### Question 1: Is there evidence on rates of occurrence of visually significant PCO?

Twelve unique articles addressed this question (Allen and Zhang, 1987; Frezzotti and Caporossi, 1990; Kooner, Dulaney, and Zimmerman, 1988; Moisseiev, Bartov, Schochat et al., 1989; Moschos, 1988; Naeser, Rask, and Hansen, 1986a [identical data reported in Naeser, Rask, and Hansen, 1986b]; Sellman and Lindstrom, 1988; Story, 1988; Straatsma, Meyer, Bastek et al., 1983; Sudhakar, Ravindran, and Natchiar, 1989; Van Oye, Budo, Galand et al., 1986; Watts, 1986). Undefined outcome, patient dropout, undefined PCO, and lack of adjustment for variation in followup time made the rate of occurrence of PCO difficult to assess. In the absence of a definition of, or a variation in the definition of, a visually significant PCO, it is likely that there is a wide variation in what is considered visually significant. Most of the studies lack a definition of this outcome. Many studies simply refer to the time of YAG capsulotomy as a surrogate for this outcome, which may be quite inaccurate. Followup time ranged from 2 weeks to 5 years, with capsular opacification rates varying from 2 to 16 percent at 1 year and up to 41 percent at 4 years. The data suggest that the incidence of visually significant PCO increases in direct proportion to postoperative followup time (Table 8-1). One paper (Frezzotti and Caporossi, 1990) suggested that patients younger than 40 years had a higher rate of visually significant PCO.

Table 8-1. PCO Incidence After Cataract Surgery

Source | Cataract Surgery | Average Followup (Months) | PCO Incidence Information
Naeser, Rask, and Hansen, 1986a | ECCE/IOL | 4 | 3.0 percent PCO requiring YAG
Naeser, Rask, and Hansen, 1986b | -- | -- | 12.1 percent moderate PCO without YAG
Sellman and Lindstrom, 1988 | ECCE/IOL | 12 | 7.1-16.1 percent moderate/severe Elschnig pearl migration; 2.4-4.4 percent capsular fibrosis
Watts, 1986 | ECCE/IOL | 17 | 2-4 percent capsular membrane thickening
Kooner, Dulaney, and Zimmerman, 1988 | ECCE/IOL | 18 | 15 percent posterior capsule haze
Van Oye, Budo, Galand et al., 1986 | ECCE/IOL | 24 (minimum) | 9.8 percent requiring YAG; 20.1 percent PCO without YAG
Story, 1988 | ECCE/IOL | 32 | 4.1 percent requiring discission due to VA <20/40 or PCO-related symptoms
Moisseiev, Bartov, Schochat et al., 1989 | ECCE or ECCE/IOL | 48 (minimum) | 41 percent PCO requiring capsulotomy
Frezzotti and Caporossi, 1990 | ECCE or ECCE/IOL | 60 (minimum) | 7.7-14.2 percent PCO

Note: ECCE = Extracapsular cataract extraction. IOL = Intraocular lens. PCO = Posterior capsular opacification. VA = Visual acuity. YAG = Yttrium aluminum garnet.

#### Question 2: Is there evidence on timing and rates of performance of YAG capsulotomy?

The performance of YAG capsulotomy is an objectively identifiable endpoint, unlike the more subjective determination of the onset of visually significant PCO; however, there is wide intersurgeon variation in the criteria used to determine when this procedure is warranted. Lack of information on these criteria or use of subjective criteria (such as the surgeon's determination that the PCO was "significant") is the most critical unknown in the 30 studies that include information on the timing and rates of performance of YAG capsulotomy (Aron-Rosa, 1985; Brown, Thomas, Belcher et al., 1985; Burratto, Ricci, and Vitali, 1985; Capone, Rehkopf, Warnicki et al., 1990; Chambless, 1985; Coonan, Fung, Webster et al., 1985; Davison, 1988; Downing, 1986; Durham and Gills, 1985 [identical data reported in Shah, Gills, Durham et al., 1986]; Flohr, Robin, and Kelley, 1985; Fourman and Apisson, 1991; Gardner, Straatsma, and Pettit, 1985; Javitt, Tielsch, Canner et al., 1992; Knolle, 1985; Koch, Liu, Gill et al., 1989; Leff, Welch, and Tasman, 1987; Lewis, Singer, Hanscom et al., 1987; Liesegang, Bourne, and Ilstrup, 1985; Maltzman, Haupt, and Cucci, 1989; Maltzman, Haupt, and Notis, 1989; Milauskas, 1987; Naeser, Rask, and Hansen, 1986a; Richter, Arzeno, Pappas et al., 1985a; Schubert, 1987; Shepherd, 1989b; Slomovic, Parrish, Forster et al., 1986; Steinert, Puliafito, Kumar et al., 1991; Stern, Taylor, and Bernstein, 1985; Van Oye, Budo, Galand et al., 1986; Wright, Wilkinson, Balyeat et al., 1988). The study by Javitt et al. (Javitt, Tielsch, Canner et al., 1992) indicates a wide range of YAG capsulotomy rates per person-year across the United States (2.5-27 percent), which is attributed to a lack of consensus on timing and indications for the procedure. There is a need to explain the twofold-to-sevenfold increase in rates of YAG capsulotomy between contiguous States such as Utah and Nevada. Perhaps because of intersurgeon variation, time-specific estimates of rates of performing YAG vary widely. Furthermore, only one study adjusted for censoring and variable followup, so most rate estimates are crude at best (Javitt, Tielsch, Canner et al., 1992) (Table 8-2).

Table 8-2. Incidence of YAG Capsulotomy After Cataract Extraction

Source | Cataract Surgery | Average Followup (Months) | YAG Incidence Information (Percent)
Naeser, Rask, and Hansen, 1986a[1] | ECCE/IOL (N=66 eyes) | Mean=4 | 3
Milauskas, 1987 | ECCE/IOL (N=732 eyes) | Mean=9 | 7.0-27.9
Van Oye, Budo, Galand et al., 1986 | ECCE/IOL (N=214 eyes) | 24 (minimum) | 9.8
Downing, 1986 | ECCE/IOL (N=757 eyes) | 12-62 | 11.2
Maltzman, Haupt, and Cucci, 1989 | ECCE/IOL (N=187 eyes) | Mean=24 | 15.1-20.8
Davison, 1988 | ECCE (N=3,120 eyes) | At least 12 | 16.1
Shepherd, 1989b | ECCE/IOL (N=228 eyes) | 12 (all eyes) | 4.8-16.5
Coonan, Fung, Webster et al., 1985 | ECCE (N=842 eyes) | Mean=32 (at least 12) | 16.7
Javitt, Tielsch, Canner et al., 1992 | ECCE (N=55,103 eyes) | Mean=24 (range, 12-36) | 24
Wright, Wilkinson, Balyeat et al., 1988 | ECCE/IOL (N=50 eyes) | 6 (all eyes) | 38
Fourman and Apisson, 1991 | ECCE/IOL (N=732 eyes) | Not reported | 53

[1] Identical data reported in Naeser, Rask, and Hansen, 1986b.

Note:ECCE = Extracapsular cataract extraction, IOL = Intraocular lens, YAG = Yttrium aluminum garnet.

In general, the need for YAG capsulotomy increases with increasing time after cataract surgery, with the larger studies reporting a crude incidence of 15-20 percent approximately 2 years after surgery (Table 8-3). The median and range of time from cataract surgery to YAG capsulotomy for the 22 studies that reported an average and/or range were 24 months and 1-600 months, respectively. Little information exists on the role of patient factors on the rate or timing of YAG capsulotomy.

Table 8-3. Timing of YAG Capsulotomy After Cataract Extraction (Months)

Source | Average Interval | Standard Deviation | Range
Coonan, Fung, Webster et al., 1985 | 24 | NR | 2-88
Ambler and Constable, 1988 | 24 | NR | 4-47
Chambless, 1985 | NR | NR | 1.5-114
Stern, Taylor, and Bernstein, 1985 | 24 | NR | 2-69
Knolle, 1985 | 25-36 | NR | 3-72
Flohr, Robin, and Kelley, 1985 | 26 | 17 | 3-106
Slomovic, Parrish, Forster et al., 1986 | 24 | NR | 2-360
Durham and Gills, 19851 | 24 | NR | 2-72
Aron-Rosa, 1985 | NR | NR | 7-420
Koch, Liu, Gill et al., 1989 | 27 | NR | 3-124
Gardner, Straatsma, and Pettit, 1985 | 13 | NR | 1-600
Brown, Thomas, Belcher et al., 1985 | 15 | NR | 3-36
Leff, Welch, and Tasman, 1987 | 15 | NR | 2-68
Capone, Rehkopf, Warnicki et al., 1990 | 23 | NR | 8-38
Javitt, Tielsch, Canner et al., 1992 | 12 | 08 | 0-24
Fourman and Apisson, 1991 | 17 | 12 | NR
Liesegang, Bourne, and Ilstrup, 1985 | 34 | NR | NR
Burratto, Ricci, and Vitali, 1985 | 17 | NR | NR
Maltzman, Haupt, and Notis, 1989 | 24 | NR | NR
Schubert, 1987 | 23 | 03 | NR
Richter, Arzeno, Pappas et al., 1985a | 12 | 03 | NR
Lewis, Singer, Hanscom et al., 1987 | 13 | NR | 4-54

[1] Identical data reported in Shah, Gills, Durham et al., 1986.

Note: NR = Not reported.

#### Question 3: Is there evidence on indications, complications, and outcomes after YAG capsulotomy?

Fifty-seven studies address this question (Albert, Wade, Parrish et al., 1990; Ambler and Constable, 1988; Aron-Rosa, 1985; Axt, 1985; Bath and Fankhauser, 1986; Boen-Tan and Stilma, 1986; Brown, Stewart, Lynch et al., 1988; Brown, Thomas, Belcher et al., 1985; Burratto, Ricci, and Vitali, 1985; Canning, Capon, Sherrard et al., 1988; Capone, Rehkopf, Warnicki et al., 1990; Chambless, 1985; Channell and Bechman, 1984; Clorfeine and Parker, 1984; Corboy and Novak, 1989; Dardenne, Gerten, Kokkas et al., 1989; Deutsch and Goldberg, 1985; Durham and Gills, 1985 [identical data reported in Shah, Gills, Durham et al., 1986]; Ficker and Steele, 1985; Flohr, Robin, and Kelley, 1985; Fourman and Apisson, 1991; Gardner, Straatsma, and Pettit, 1985; Harris, Herman, and Fagadau, 1985; Javitt, Tielsch, Canner et al., 1992; Katzen, Fleischman, and Trokel, 1983; Knighton, Slomovic, and Parrish, 1985; Knolle, 1985; Koch, Liu, Gill et al., 1989; Kraff, Sanders, and Lieberman, 1985; Leff, Welch, and Tasman, 1987; Levy and Dodick, 1984; Levy and Pisacano, 1985; Lewis, Singer, Hanscom et al., 1987; Leys, Pameijer, and de Jong, 1985; Liesegang, Bourne, and Ilstrup, 1985; MacEwen and Baines, 1989; Maltzman, Haupt, and Cucci, 1989; Maltzman, Haupt, and Notis, 1989; Migliori, Beckman, and Channell, 1987; Milauskas, 1987; Nirankari and Richards, 1985; Ober, Wilkinson, Fiore et al., 1986; Peyman, Caldwell, Conway et al., 1985; Pollack, Brown, Crandall et al., 1989 [identical data reported in Pollack, Brown, Crandall et al., 1988]; Richter, Arzeno, Pappas et al., 1985a and 1985b; Rickman-Barger, Florine, Larson et al., 1989; Schubert, 1987; Shepherd, 1989b; Silverstone, Novack, Kelley et al., 1988; Slomovic and Parrish, 1985; Slomovic, Parrish, Forster et al., 1986; Stark, Worthen, Holladay et al., 1985; Steinert, Puliafito, Kumar et al., 1991; Stern, Taylor, and Bernstein, 1985; Stilma and Boen-Tan, 1986; Wasserman, Axt, and Sheets, 1985).

Most of the articles that included information on the indication for YAG capsulotomy made reference to some form of interference with the patient's ability to see well. In the two articles wherein this interference was quantified, the most prevalent measure used was best corrected visual acuity of 20/50 or worse in the presence of "significant" PCO (Maltzman, Haupt, and Cucci, 1989; Stern, Taylor, and Bernstein, 1985), whereas glare, light sensitivity, and/or hazy vision without decreased visual acuity were mentioned but not quantified in five papers (Chambless, 1985; Maltzman, Haupt, and Cucci, 1989; Maltzman, Haupt, and Notis, 1989; Milauskas, 1987; Shepherd, 1989b). Most articles either did not indicate the reason for YAG capsulotomy (n=13) or indicated that the reason for YAG capsulotomy was an opacified posterior capsule (n=6) or a clinical judgment (n=4).

Complications and outcomes of YAG capsulotomy were addressed in all of the 57 articles. Whereas the information on intraoperative and early postoperative complications is good in quality and comprehensive in scope, limited information exists on long-term complications. That which exists suffers from incomplete followup and uncertainties about the content and frequency of followup examinations. In addition, the literature showed that patient characteristics affect the incidence of complications. The rate of occurrence of complications following YAG capsulotomy is shown in Table 8-4.

Table 8-4. Complications of YAG Capsulotomy

Complication | Rate of Occurrence (Percent)
Complication | Lowest | Highest
Increased glare | Rare | Rare
Retinal detachment | 0 | 4.1
Cystoid macular edema | 0 | 6.8
Endothelial cell loss | 0 | 7
Uveitis | < 0.1 | 30
Corneal edema | 1 | 2.4
Hyphema | 1 | 9
Intraocular pressure elevation | 2 | 95
Intraocular lens damage | 4.4 | 95
Anterior vitreous rupture | 6 | 41

Note: YAG = Yttrium aluminum garnet.

Source: Compiled from 57 reviewed articles and panel consensus.

The literature on outcomes and complications is discussed according to those articles that addressed elevated intraocular pressure (IOP) and retinal detachment and those that evaluated other outcomes and/or complications.

Elevated IOP: The most frequently studied complication of YAG capsulotomy is elevated IOP, with 37 articles included in this review (Aron-Rosa, 1985; Axt, 1985; Bath and Fankhauser, 1986; Boen-Tan and Stilma, 1986; Brown, Stewart, Lynch et al., 1988; Brown, Thomas, Belcher et al., 1985; Burratto, Ricci, and Vitali, 1985; Canning, Capon, Sherrard et al., 1988; Chambless, 1985; Channell and Bechman, 1984; Deutsch and Goldberg, 1985; Durham and Gills, 1985 [identical data reported in Shah, Gills, Durham et al., 1986]; Ficker and Steele, 1985; Flohr, Robin, and Kelley, 1985; Fourman and Apisson, 1991; Gardner, Straatsma, and Pettit, 1985; Harris, Herman, and Fagadau, 1985; Knolle, 1985; Kraff, Sanders, and Lieberman, 1985; Levy and Dodick, 1984; Levy and Pisacano, 1985; Leys, Pameijer, and de Jong, 1985; Liesegang, Bourne, and Ilstrup, 1985; Migliori, Beckman, and Channell, 1987; Nirankari and Richards, 1985; Peyman, Caldwell, Conway et al., 1985; Pollack, Brown, Crandall et al., 1989 [identical data reported in Pollack, Brown, Crandall et al., 1988]; Richter, Arzeno, Pappas et al., 1985a and 1985b; Schubert, 1987; Silverstone, Novack, Kelley et al., 1988; Slomovic and Parrish, 1985; Stark, Worthen, Holladay et al., 1985; Steinert, Puliafito, Kumar et al., 1991; Stern, Taylor, and Bernstein, 1985; Stilma and Boen-Tan, 1986; Wasserman, Axt, and Sheets, 1985).

Since definitions vary widely on what is considered "elevated IOP" and since even in the early postoperative period the timing of IOP measurement varied considerably, the IOP data are difficult to evaluate. The studies indicate that IOP may be elevated significantly during the first 24-48 hours after YAG capsulotomy. A report on one series of 66 patients (Slomovic and Parrish, 1985) that defined increased IOP as at least 5 mmHg over pre-YAG IOP showed a frequency of 53 percent at 1 hour, 65 percent at 2 hours, 61 percent at 3 hours, 55 percent at 4 hours, and 20 percent at 24 hours. The degree to which these elevations persist in patients is a topic of current study, and a recent article (Steinert, Puliafito, Kumar et al., 1991) reported an incidence of 1.3 percent new glaucoma or worsened preexisting glaucoma in 897 eyes that had undergone YAG capsulotomy. Most articles, however, report that early postoperative IOP elevations were responsive to treatment. Late onset (occurring 6 months or more after YAG capsulotomy) of elevated IOP was noted in 5.9 percent of 237 eyes that had undergone extracapsular cataract extraction (ECCE) with later YAG capsulotomy (Fourman and Apisson, 1991).

Retinal Detachment: Information on retinal detachment after YAG capsulotomy was reported in 16 articles (Ambler and Constable, 1988; Axt, 1985; Bath and Fankhauser, 1986; Chambless, 1985; Dardenne, Gerten, Kokkas et al., 1989; Durham and Gills, 1985; Harris, Herman, and Fagadau, 1985; Javitt, Tielsch, Canner et al., 1992; Knolle, 1985; Koch, Liu, Gill et al., 1989; Leff, Welch, and Tasman, 1987; MacEwen and Baines, 1989; Ober, Wilkinson, Fiore et al., 1986; Rickman-Barger, Florine, Larson et al., 1989; Stark, Worthen, Holladay et al., 1985; Steinert, Puliafito, Kumar et al., 1991). Except for the study by Javitt et al. (Javitt, Tielsch, Canner et al., 1992), no articles accounted for variable followup and censoring in the analysis, resulting in incidence estimates that are crude at best. Those studies that followed series of YAG patients reported a crude retinal detachment incidence ranging from 0 to 4.1 percent, whereas the 36-month post-ECCE probability of retinal detachment in patients who required YAG capsulotomy was 1.8 percent (Javitt, Tielsch, Canner et al., 1992). For this occurrence, five articles (Dardenne, Gerten, Kokkas et al., 1989; Javitt, Tielsch, Canner et al., 1992; Leff, Welch, and Tasman, 1987; MacEwen and Baines, 1989; Rickman-Barger, Florine, Larson et al., 1989) evaluated risk factors, including high myopia, younger age, male sex, lattice degeneration, and a history of retinal detachment in the fellow eye. However, estimates of relative risk are available only in the study by Javitt et al. (Javitt, Tielsch, Canner et al., 1992), which could not address clinical variables not present in the Medicare data base. In that study, patients who underwent YAG capsulotomy had a 3.9-fold increase in retinal detachment risk when compared with ECCE patients who did not undergo this procedure. This risk was independent of other significant factors that increased the post-ECCE risk of retinal detachment, including younger age, male sex, and white race.

Other Outcomes and/or Complications: Other outcomes and complications included improved visual acuity, opening of the posterior capsule, improved glare threshold, uveitis, intraocular lens (IOL) damage, cystoid macular edema, vitreous prolapse, endothelial cell loss, hyphema, and pupillary block. Visual acuity improvement was noted in 22 articles (Albert, Wade, Parrish et al., 1990; Axt, 1985; Bath and Fankhauser, 1986; Burratto, Ricci, and Vitali, 1985; Capone, Rehkopf, Warnicki et al., 1990; Chambless, 1985; Deutsch and Goldberg, 1985; Durham and Gills, 1985; Flohr, Robin, and Kelley, 1985; Gardner, Straatsma, and Pettit, 1985; Harris, Herman, and Fagadau, 1985; Katzen, Fleischman, and Trokel, 1983; Knighton, Slomovic, and Parrish, 1985; Knolle, 1985; Levy and Dodick, 1984; Levy and Pisacano, 1985; Nirankari and Richards, 1985; Peyman, Caldwell, Conway et al., 1985; Stark, Worthen, Holladay et al., 1985; Steinert, Puliafito, Kumar et al., 1991; Stern, Taylor, and Bernstein, 1985; Wasserman, Axt, and Sheets, 1985), and improvement was observed in 65-100 percent of those undergoing YAG capsulotomy. However, variation in followup after YAG capsulotomy was considerable, and losses to followup were often substantial. Reporting of both pre- and post-YAG visual acuity was often lacking, and when present, often categorical rather than patient specific. Capsular opening was specified in four papers and ranged from 97 to 100 percent (Capone, Rehkopf, Warnicki et al., 1990; Gardner, Straatsma, and Pettit, 1985; Lewis, Singer, Hanscom et al., 1987; Stark, Worthen, Holladay et al., 1985). An increase in the glare threshold after YAG capsulotomy was noted in two articles (Capone, Rehkopf, Warnicki et al., 1990; Knighton, Slomovic, and Parrish, 1985).

Other than IOP elevation, the most commonly reported complication was damage to the patient's IOL, which was reported in 20 unique articles with a frequency ranging from 4.4 to 95 percent (Aron-Rosa, 1985; Axt, 1985; Bath and Fankhauser, 1986; Burratto, Ricci, and Vitali, 1985; Chambless, 1985; Corboy and Novak, 1989; Deutsch and Goldberg, 1985; Durham and Gills, 1985 [identical data reported in Shah, Gills, Durham et al., 1986]; Flohr, Robin, and Kelley, 1985; Gardner, Straatsma, and Pettit, 1985; Harris, Herman, and Fagadau, 1985; Levy and Dodick, 1984; Levy and Pisacano, 1985; Lewis, Singer, Hanscom et al., 1987; Liesegang, Bourne, and Ilstrup, 1985; Nirankari and Richards, 1985; Peyman, Caldwell, Conway et al., 1985; Stark, Worthen, Holladay et al., 1985; Stern, Taylor, and Bernstein, 1985; Wasserman, Axt, and Sheets, 1985). The damage usually took the form of minor surface pitting. Two articles (Gardner, Straatsma, and Pettit, 1985; Nirankari and Richards, 1985) reported lost vision in two patients due to the IOL damage. Rupture of the anterior vitreous face was noted in eight papers (Bath and Fankhauser, 1986; Ficker and Steele, 1985; Harris, Herman, and Fagadau, 1985; Koch, Liu, Gill et al., 1989; Lewis, Singer, Hanscom et al., 1987; Nirankari and Richards, 1985; Schubert, 1987; Stark, Worthen, Holladay et al., 1985), with a frequency ranging from 6 to 41 percent of eyes.

Ten unique articles (Albert, Wade, Parrish et al., 1990; Axt, 1985; Bath and Fankhauser, 1986; Chambless, 1985; Durham and Gills, 1985 [identical data reported in Shah, Gills, Durham et al., 1986]; Harris, Herman, and Fagadau, 1985; Knolle, 1985; Levy and Pisacano, 1985; Lewis, Singer, Hanscom et al., 1987; Steinert, Puliafito, Kumar et al., 1991) evaluated the post-YAG frequency of cystoid macular edema, but because of the unavailability of pre-YAG angiographic documentation in all but one article (Albert, Wade, Parrish et al., 1990), the postoperative rates of cystoid macular edema (which ranged from 0 to 6.8 percent) cannot be interpreted as incidence estimates.

Eleven articles (Axt, 1985; Burratto, Ricci, and Vitali, 1985; Chambless, 1985; Gardner, Straatsma, and Pettit, 1985; Harris, Herman, and Fagadau, 1985; Levy and Dodick, 1984; Levy and Pisacano, 1985; Lewis, Singer, Hanscom et al., 1987; Peyman, Caldwell, Conway et al., 1985; Stark, Worthen, Holladay et al., 1985; Wasserman, Axt, and Sheets, 1985) reported on post-YAG uveitis, which was usually mild and was found in 1-30 percent of examined eyes at variable post-YAG time periods. The definition of uveitis was not standardized. Corneal endothelial cell loss was reported in five articles (Axt, 1985; Kraff, Sanders, and Lieberman, 1985; Liesegang, Bourne, and Ilstrup, 1985; Slomovic, Parrish, Forster et al., 1986; Wasserman, Axt, and Sheets, 1985) and ranged from 0 to 7 percent. Mild transitory corneal edema ranging from 1 to 2.4 percent was reported in three articles (Levy and Dodick, 1984; Levy and Pisacano, 1985; Liesegang, Bourne, and Ilstrup, 1985), and iris bleeding with hyphema ranging from 1 to 2.4 percent was noted in seven papers (Bath and Fankhauser, 1986; Deutsch and Goldberg, 1985; Flohr, Robin, and Kelley, 1985; Gardner, Straatsma, and Pettit, 1985; Harris, Herman, and Fagadau, 1985; Levy and Pisacano, 1985; Nirankari and Richards, 1985). The association of preoperative ocular, systemic, or demographic factors with the risk of YAG-related complications received little attention in this literature.

The quality of information in the large number of articles that describe intraoperative and early postoperative complications and visual acuity results is quite good (see Table 8-4). However, the manner in which data are presented on the IOP rise during the first 24-48 hours varies somewhat. The accuracy and comparability of estimated rates of longer term complications and outcomes are affected by incomplete followup and uncertainties regarding the frequency and content of followup examinations. Only one (Javitt, Tielsch, Canner et al., 1992) of the studies of retinal detachment after YAG capsulotomy adjusted for variable followup, so the estimates are affected by this factor. Definitions of some outcomes (e.g., uveitis) are not standardized, and postoperative incidence estimates of cystoid macular edema are suspect in those studies that lack complete pre-YAG angiography. Patient characteristics may affect the incidence of complications.

#### Question 4: Is there evidence on rates of occurrence of PCO in relation to IOL design?

Of the 10 unique articles (Downing, 1986; Liesegang, Bourne, and Ilstrup, 1985; Maltzman, Haupt, and Cucci, 1989; Milauskas, 1987; Naeser, Rask, and Hansen, 1986a [identical data reported in Naeser, Rask, and Hansen, 1986b]; Sellman and Lindstrom, 1988; Shepherd, 1989b; Story, 1988; Van Oye, Budo, Galand et al., 1986; Watts, 1986) that evaluated the role of IOL design in opacification of the posterior capsule, all but one were retrospective in design and employed subjective criteria for defining either opacification or the need for YAG capsulotomy. Outcome assessment was not masked with regard to IOL design in any study, and followup varied in duration and completeness. The comparability of patients receiving the alternative IOL designs was provided for in only the single clinical trial (Sellman and Lindstrom, 1988). Three studies (Downing, 1986; Liesegang, Bourne, and Ilstrup, 1985; Sellman and Lindstrom, 1988) compared lens designs that provided contact with the posterior capsule with a design that did not, and a fourth study (Shepherd, 1989b) compared sulcus-fixed with bag-fixed lenses. All four reported higher rates of opacification or YAG capsulotomy with the lenses that were not in contact with the posterior capsule. Because of serious methodologic deficiencies in these studies, any conclusions must await confirmation by further, well-designed studies.

Methodologic deficiencies in the studies that attempted to address this question precluded any conclusions regarding the relationship of PCO to IOL design.

#### Question 5: Is there information on cost and/or cost-benefit issues?

Only one article (Rich, 1987) was identified on this topic, comparing direct costs of inpatient surgery for posterior capsulotomy using non-YAG procedures with outpatient surgery using a YAG laser. No attempt was made to estimate indirect costs associated with either approach, and direct-cost capture was incomplete and crude at best. Benefits are not addressed in economic terms.

## Conclusions of the Panel

In light of the evidence from the literature review, the panel reached the following conclusions by consensus.

- Opacification of the posterior capsule is a consequence of modern cataract surgery. As the opacification increases, the patient begins to notice a decrease in visual function that can lead to functional impairment.
- The time of onset of capsular opacification after cataract surgery is quite variable, as is the frequency with which YAG capsulotomy is performed.
- The diagnosis of functional impairment due to capsular opacification is made based on clinical judgment regarding visual loss and/or symptoms of glare and symptoms of decreased contrast in combination with the appearance of the posterior capsule.
- Capsular opacification severe enough to impair function significantly and thus require YAG capsulotomy should be a rare occurrence within 3 months of modern cataract surgery and uncommon in the first 6 months. Based on data in the literature, the rate in the first 2 years after surgery appears to be less than 25 percent. However, the panel has no basis for determining whether this is the optimum rate for YAG capsulotomy over this period.
- YAG capsulotomy is an effective procedure when used appropriately. However, it is subject to complications, some of which, though not common, are potentially blinding.

## Recommendations for Care

The panel agreed unanimously that laser capsulotomy is a surgical procedure because:

- Its performance requires preoperative evaluation and diagnosis and formal patient education and consent.
- It involves destruction or cutting of ocular tissue.
- It alters tissue relationships within the eye.
- It is subject to immediate and long-term complications that require diagnosis and management and that are potentially threatening to vision.

The panel concurred that the approach to the management of functional impairment due to PCO is similar to that of functional impairment due to cataract and that management should be considered under the following headings:

- Diagnosis.
- Indications for surgery.
- Contraindications.
- Preoperative evaluations.
- Surgical technique and complications.
- Postoperative care and long-term followup.
- Benefits and harms.

### Diagnosis

The diagnosis of functional impairment due to PCO is made in the context of a patient who had previously undergone cataract surgery and who now has an opacified posterior capsule. The same general approach as that outlined for cataract should be followed. However, the patients who have PCO differ from those with cataract in an important way. Generally, PCO develops more rapidly than cataract. Thus, the patient with PCO has enjoyed improved vision in the more recent past. Therefore, in this context, diagnosis involves a consideration of the following:

- The degree of functional impairment.
- The amount of PCO.
- Other possible causes of decreased vision following cataract surgery.

The panel concurred with the finding of the literature review that there is yet no objective method of relating the degree of capsular opacification to the severity of functional impairment.

### Indications for Surgery

Laser capsulotomy is appropriate and justified when the following subjective, objective, and educational criteria are met, as outlined in Indications for Surgery in Chapter 5.

- Subjective: The ability to carry out needed or desired activities is impaired.
- Objective: The eye examination confirms the diagnosis of PCO and excludes other ocular causes of functional impairment.
- Educational: The patient has been educated about the risks and benefits of laser surgery to the posterior capsule.

The patient determines if the expected improvements in the disability outweigh the risks and costs of laser surgery.

Occasionally, laser capsulotomy is indicated for reasons other than improving functional disability -- to provide a better visualization of the posterior pole to diagnose and treat retinal detachment, macular disease, and diabetic retinopathy; to evaluate the optic nerve head; and to diagnose posterior pole tumors or other conditions requiring ophthalmologic evaluation.

### Contraindications

The panel concurred that there are no absolute contraindications to the performance of YAG capsulotomy in an appropriately diagnosed and informed patient, i.e., a patient who has undergone uncomplicated modern cataract surgery -- extracapsular technique or phacoemulsification (PE). However, incisional capsulotomy may be indicated in those patients who cannot comply with the requirements for YAG capsulotomy by reason of physical or mental impairment or whose membrane thickness precludes successful laser surgery. YAG capsulotomy should not be performed prophylactically or scheduled routinely at particular times after cataract surgery. For reasons of improving functional impairment, it should seldom be necessary in the first 3 months after surgery and should be infrequently required prior to 6 months. Based on data in the published literature (see Table 8-3), the rate in the first 2 years is less than 25 percent. However, the panel has no basis for determining whether this is the best possible rate. The time at which PCO may require laser surgery cannot be predicted, and it is seldom indicated before 3 months after surgery. Additionally, laser surgery carries its own risks. Therefore, laser capsulotomy should never be scheduled at the time cataract surgery is scheduled or performed. Justification for performing the procedure should be well documented in the patient's record. This is particularly important in light of the recent evidence of an overall increased risk of retinal detachment following YAG capsulotomy (Javitt, Tielsch, Canner et al., 1992).

### Preoperative Ophthalmic Evaluation

The panel did not evaluate the use of tests of contrast sensitivity, glare, and potential vision in the management of PCO. Fluorescein angiography may be indicated when there is clinical evidence of macular disease and/or the degree of capsular opacity appears insufficient to account for the level of decreased visual acuity. This should be documented in the chart. B-scan ultrasonography is indicated when the degree of capsular opacification is of a severity that the posterior pole cannot be visualized and when the degree of central visual loss is severe and seemingly unexplained by the degree of opacification. The preoperative ophthalmic evaluation should include a history and complete ocular examination.

### Preoperative Medical Evaluation

YAG capsulotomy is a surgical procedure that is performed without the need for regional anesthesia other than an application of topical anesthetic to the cornea. However, vasoactive drugs (e.g., aproclonidine and beta-adrenergic blocking agents) are commonly used in the perioperative period. The panel concurs that it is the responsibility of the ophthalmologist who will perform the laser surgery to assess the medical suitability of the patient for the procedure and the use of these agents in the perioperative phase.

### Surgical Technique

Laser surgery of the posterior capsule is performed in the office, ambulatory surgical center, or a hospital outpatient department, under biomicroscopic magnification. A contact lens may be used to enhance visualization of the posterior capsule and help stabilize the eye during the procedure. The literature search did not address technical aspects of the surgical procedure. However, the panel concurred that careful consideration should be given to the amount of energy used, the size of the opening, and its location, since these may influence the subsequent risk of complications.

### Complications

The major complications of YAG laser capsulotomy include elevated IOP, retinal detachment, cystoid macular edema, damage to the IOL, hyphema, dislocation of the IOL, and corneal edema.

### Postoperative Care

The ophthalmologist who performed the laser capsulotomy has an ethical and legal responsibility to provide postoperative care to the patient. The postoperative period is considered to extend 2 weeks from the end of the procedure. If complications develop (e.g., persistent elevated IOP, retinal detachment, cystoid macular edema, or corneal abrasion), the ophthalmologist has the obligation to provide appropriate care or, with the patient's consent, to refer to another ophthalmologist.

#### Postoperative Care (Immediate).

Patients who have undergone laser capsulotomy must be observed for at least 1 hour for evidence of elevated IOP. If the pressure is elevated, appropriate treatment must be instituted and the patient followed until the problem is resolved.

#### Postoperative Care (1-2 Weeks).

Within 2 weeks of the procedure, the patient should be reexamined by the ophthalmologist who performed the laser capsulotomy, and the eye should be refracted as necessary. The examination should also include measurement of IOP, slit lamp examination of the anterior segment to confirm the adequacy of laser capsulotomy and stability of the IOL, and indirect ophthalmoscopy for retinal tears or detachment. In light of the increased risk of retinal detachment after YAG capsulotomy, patients should be instructed about symptoms of retinal detachment and the need for immediate examination if they develop. Patients should also be instructed about the slight long-term risks of glaucoma and complications and about the need for periodic eye examinations.

### Benefits and Harms of YAG Capsulotomy

As in the case of cataract surgery, there are no data that precisely define the risk and benefits of YAG capsulotomy. However, some estimates can be made based on literature reports of outcomes and complications.

#### Benefits: Positive Outcomes.

YAG capsulotomy is a highly successful procedure. In eyes without comorbidity, a visual improvement can be expected in greater than 65 percent of the cases. The same positive outcomes as outlined in the section on positive outcomes for cataract surgery apply to YAG capsulotomy (see Surgical Techniques and Complications in Chapter 5).

#### Harms: Negative Outcomes.

Harms that may occur as a result of YAG capsulotomy may be defined as negative outcomes. These include failure to achieve expected positive outcomes or failure to relieve or improve the preoperative functional impairment as perceived by the patient, the patient's family, or the ophthalmologist who performed the YAG capsulotomy. In addition, negative outcomes refer to the development of complications that either impair the patients' visual function or consume their resources Table 8-5. It should be noted that these complication rates are based on data obtained from the literature review and the consensus of the panel. Therefore, they should be considered only estimates.

Table 8-5. Estimated Rate of Negative Outcomes of YAG Capsulotomy

>= 1:100 | < 1:100 | < 1:10,000 | < 1:100,000
Glaucoma | Retinal detachment | Double vision | Loss of eye
Failure to improve | Problems with glare | Dislocated lens | Chronic pain
Increased need for medication | Cystoid macular edema | Disorientation | Depression
Adverse effects from the drugs used in treatment | Need for further surgery | Clinically significant damage to intraocular lens | Psychosis
Adverse effects from the drugs used in treatment | Loss of permanent vision | | Suicide

Note: Except for failure to improve, disorientation, and clinically significant damage to intraocular lens, the rate increases when there are comorbid conditions. The rate < 1:1,000 is not applicable to this table. YAG = Yttrium aluminum garnet.

Source: Compiled from reviewed literature and panel consensus.

The success rate of YAG capsulotomy is reduced in the presence of comorbid ocular conditions. Again, data are lacking to give precise estimates of this effect, but outcome is influenced by conditions such as corneal disease leading to loss of corneal clarity, preexisting glaucoma, and preexisting retinal disorders such as retinal detachment disease, macular degeneration, and diabetic retinopathy. Each contributes to a loss of vision and, therefore, to a loss of the effect of the YAG capsulotomy. This may be immediate (that is, proximal to the time of surgical effect) or may be manifested a considerable time after the YAG capsulotomy is complete.

In considering all possible benefits and harms, these conditions must be taken into account. The degree to which they are treated or will be treated will influence the outcome. Overall, in the presence of these conditions, the success rate of the YAG capsulotomy is reduced compared with the overall high level of the expected outcome in the eye without these comorbid conditions.

## Recommendations for Research

The findings from the literature review indicate that there are wide variations in rates and timing of YAG capsulotomy after cataract surgery. This suggests the possibility of inappropriate use of this procedure. Therefore, the panel recommends that research be undertaken to evaluate the factors that influence the decision to proceed with YAG capsulotomy, including the physician, the patient, and the eye-related factors, with special emphasis on variation in physician procedure patterns related to geographic location.

The panel recommends that research be undertaken to identify risk factors for PCO and to develop measures that reduce or eliminate PCO.

The panel also recommends that research be undertaken to establish the relationship of specific aspects of the surgical technique of laser capsulotomy to the risk of complications.