# Guideline: Rehabilitation

Numerous factors need to be considered to successfully rehabilitate the cataract patient.

## Background

Outpatient cataract surgery became a reality without consideration for the rehabilitation needs of the postoperative patient. Previously, the patient enjoyed the collaborative efforts of the health care team (medical doctor, registered nurse, medical social worker, and registered dietician) preoperatively and postoperatively in the hospital setting. Upon the patient's admission for an inpatient stay, the role of the registered nurse included an assessment involving evaluation of functional limitations; exploration of potential environmental and economic concerns; and consideration of cultural, ethnic, and psychosocial factors. Compilation of these data was the basis for a discharge plan.

Postoperatively, the plan was expanded to include the appropriate education for continuation of any necessary treatments (e.g., instructions for proper instillation of eye medications and systemic medication regimen). Elimination of the traditional hospital admission procedures automatically led to discontinuance of this approach to discharge planning. Thus, planning for immediate and long-term postoperative needs became the surgeon's responsibility. Presently, the surgeon and office team are relied on to educate, instruct, evaluate, and plan for all aspects of the patient's needs in a limited preoperative time period. The immediate and brief postoperative recovery phase accompanied by the compromising effects of anesthesia may discourage fruitful educational efforts or psychosocial planning. Hence, aspects of the patient's needs may be left unaddressed. The actual effects of the current modality of cataract surgery on the rehabilitation of the patient have not been studied.

There is, therefore, valid concern about a deterioration in the quality of postoperative care as a result of ineffective discharge planning (Leader, 1990).

## Literature Review

### Methods

The purpose of the literature review was to determine if there was evidence in the published literature to support or refute an association between the outcome of cataract surgery and factors affecting the rehabilitation of the patient during the postoperative period. (For a full description of the review process, see Appendix N in the Guideline Report.)

### Results

The questions identified by the panel are as follows.

Question 1: Is there evidence to support or refute an association between outcome of cataract surgery and delivery of postoperative care at home?

Question 2: Is there evidence to support or refute an association between outcome of cataract surgery and preoperative and postoperative patient and family education and counseling?

Question 3: Is there evidence to support or refute an association between outcome of cataract surgery and functional status (physical and mental) of patients at the time of surgery?

Question 4: Is there evidence to support or refute an association between outcome of cataract surgery and financial status?

Question 5: Is there evidence to support or refute an association between outcome of cataract surgery and cultural, religious, and ethnic factors?

Question 6: Is there evidence to support or refute an association between outcome of cataract surgery and the identity of the person involved in providing postoperative rehabilitation (e.g., family member, ophthalmic nurse, registered nurse, medical social worker, or social agency)?

Question 7: Is there evidence to support or refute an association between outcome of cataract surgery and the costs and benefits of formal rehabilitation programs?

Thirty-two articles underwent indepth reviews. Although they all addressed aspects of the care of patients with cataract, none satisfied the inclusion criteria as specified by the panel.

One study (Graney, Applegate, Miller et al., 1990), which failed to meet the inclusion criteria, examined preoperative predictors of surgical success in patients with cataract and retinal disease; the authors found the availability of a helper in the home was not a prognostic indicator. The description of this portion of the study and the data were insufficient to allow an assessment of the implications of this finding.

### Conclusions From the Literature Review

This literature search failed to identify evidence in the published literature to address the questions posed by the panel concerning rehabilitation of the patient undergoing cataract surgery.

## Conclusions of the Panel

The implementation of outpatient cataract surgery has adversely affected the team approach to planning the individualized rehabilitative course for many patients. The collaborative efforts of professionals to customize the discharge plan within their areas of practice, followed by appropriate evaluations and modifications, have been largely abandoned. This is especially true of the role of the ophthalmic nurse and medical social worker, who have been underutilized. Appropriate planning for postoperative rehabilitation can be accomplished by office personnel interacting with the patient and family preoperatively and postoperatively or through a multidisciplinary approach using optometrists, registered nurses, community health nurses, or social workers.

In the absence of evidence in the literature on this topic, the panel agreed that the successful rehabilitation of the cataract patient involves several factors, including compliance with physician instructions, patient education, and timely management of postoperative complications. Other factors expected to influence the rehabilitation process are economic, environmental, cultural and ethnic, and psychosocial (Whitaker and Whitaker, 1991).

### Compliance

Cataracts in adults tend to develop bilaterally, so poor vision in the unoperated eye may increase the degree of difficulty in instilling eyedrops. Conditions associated with the aging process, such as rheumatoid arthritis and diabetes, can result in peripheral nerve dysfunction and inhibit the medication instillation (Donnelly, 1987). Other sensory changes in old age may increase the patient's difficulty in understanding treatment and how to comply with instructions (Smith and Drance, 1984). Problems with speech discrimination and the increased time needed to process oral information may render rapid speech unintelligible.

### Patient Education

Careful preoperative assessment of the abilities of the patient and family to understand and comply with instructions is critical to ensuring adequate postoperative care and is the responsibility of the surgeon and his or her staff. Education for postsurgical care most appropriately begins preoperatively. However, the focus of diagnosis, surgical procedure, and visual prognosis may provide too much information for the patient to absorb. Some patients are shocked when they learn they have cataracts, and others do not even realize the extent of the visual impairment, since the deterioration is usually a gradual process (Low, 1978). Hence, preoperative education is initiated during a difficult period and may be of limited value. The postoperative cataract patient, discharge instructions in hand, may not be able to distinguish the normal from the abnormal response and may decline to contact the physician because of feelings of embarrassment or lack of understanding. The patient may have a written document listing the postoperative instructions but may not be able to read it because of reduced vision or other physical or mental problems (Smith and Drance, 1984). This may prevent the treatment from being accomplished successfully. Referral to a home health agency in such circumstances is appropriate for further education and evaluation of a patient's ability to follow discharge instructions.

### Management of Postoperative Complications

Although serious complications after modern cataract surgery are now infrequent, their occurrence is unpredictable. Lack of provisions for immediate intervention could result in an adverse surgical outcome, particularly for the patient living alone.

Coexisting medical problems, such as arthritic deformities, insulin-dependent diabetes, hypertension, cardiac disease, drug or alcohol addiction, mental illness, dementia, severe depression, or acute grief, create a complex situation for the postoperative patient. The physical limitations from a preexisting condition may limit or prevent the patient from properly complying with the required postoperative regimen. Thus, there is the potential for ineffective treatment or overdosing of medications (Hunt, 1991). It may be difficult for patients to identify labels on eyedrops because of their altered visual status postoperatively. The use of certain ophthalmic medications by patients concurrently treated with other drug therapy heightens the potential for serious adverse systemic reactions (e.g., topical beta-blocking agents added to systemic beta blockers). In the patient with delayed recovery or unrecognized postanesthetic complications, premature discharge without appropriate planning and education could be fatal.

### Economic Factors

In addition to the diagnostic and pretreatment considerations in older patients, cataract surgery may also have an adverse economic impact on patients and their families. Many patients are retired persons living on a fixed income. With the increased cost of living, some are pauperized, and others suffer significant deprivation.

Cataract surgery can present multiple problems for many patients who are ill equipped to deal with them. If they are among the "frail elderly," their needs are multiplied in the immediate postoperative period. They may need a stay in a motel for a night before surgery and a night or two after surgery. They may need assistance in the home for ambulation, transportation, meal preparation, administration of medication, and so on. These services may be unavailable for economic reasons and may or may not be reimbursed by Medicare, depending on the circumstances.

### Environmental Factors

Postoperative rehabilitation may be profoundly influenced by the patient's home environment (e.g., hazards such as broken steps, obstructed pathways, and lighting) and other factors, such as location in a high-crime area, lack of transportation, and distance from medical care support services.

### Cultural and Ethnic Factors

The diverse cultural and ethnic composition of American communities can create barriers to the effectiveness of the health care provider. There is evidence that race may be a factor in determining access to health care (Sommer, Tielsch, Katz et al., 1991). Recognizing the mores and belief systems of the patient aids in developing an appropriate plan for care ().

A substantial barrier to patient care is the inability to communicate with the health care provider. Failure to convey information effectively to non-English-speaking patients may adversely affect the rehabilitative outcomes. The needs of deaf patients should be accommodated to ensure that the information related is understood.

### Psychosocial Factors

Learning how elderly people function in their daily lives is essential to understanding and caring for them. Their hearing and vision may be impaired, their responses may be slow, and they often have chronic physical or mental illnesses with associated discomforts and difficulties in ambulation. For several reasons, elderly people may not report their symptoms. Often, they may not want to burden their family members or friends who might be their sole mode of transportation. They may be afraid or embarrassed to do so, they may be trying to avoid medical expenses or the discomforts of diagnosis and treatment, they may think that their symptoms are merely a part of the aging process, or they may have simply forgotten about their symptoms (Bates, 1987).

A significant occurrence among the aged is the tendency toward isolation: the spouse may not be alive, the extended family may live at a distance, and/or the physical environment may not be conducive to venturing outside. The fear of losing independence may deter the patient from seeking assistance from any agency before surgery. The return home postoperatively may intensify feelings of loneliness and isolation, compounded by the anxiety of the altered visual state, delayed recovery from anesthesia, and the anticipation of compliance with postoperative instructions. Referral for counseling should be made when indicated. Referral to local support groups -- such as the National Society to Prevent Blindness, Inc. (800-331-2020) -- should also be considered.

Other sensory losses cause increased difficulty in coping with the modified lifestyle. The patient with reduced vision in the unoperated eye may experience increased anxiety because of the perceived inability to dial the telephone or deal with meal preparation and other simple everyday activities. The patient may even develop psychosis due to sensory deprivation and require psychiatric consultation.

The postoperative cataract patient may have responsibilities not readily recognized by the health care team, including that of caregiver for an incapacitated spouse or child. The need to continue this status may be the principal reason for undergoing the surgery. The reality that the patient is now dependent postoperatively may create acute anxiety and an inability to cope.

## Recommendations for Care

The panel makes the following recommendations for care.

- Overall supervision of planning for postoperative rehabilitation is the responsibility of the ophthalmologist who performs the surgery. Appropriate planning for postoperative care and rehabilitation can be accomplished by office personnel who interact with the patient and family preoperatively and postoperatively or through a multidisciplinary approach utilizing optometrists, registered nurses, registered visiting nurses, or social workers.
- Careful preoperative assessment of the abilities of the patient and family to understand and comply with instructions is critical to ensuring adequate postoperative care and is the responsibility of the ophthalmologist who is to perform the surgery and his or her staff. If the patient is unable to read written instructions because of reduced vision or other physical or mental problems, referral to a home health agency is appropriate for further education and evaluation of a patient's ability to follow discharge instructions.
- Based on a thorough appraisal of household support (e.g., the patient's capacity to perform certain activities, the patient's needs and plan for care, and who is available to help), Medicare and other payers should be required to make allowances for patients requiring home care during the postoperative period, including the administration of eye medications and performance of tonometry by appropriately qualified care providers.
- Instructions regarding infection control, signs and symptoms that warrant notifying the ophthalmologist, and protective and preventive measures should be reviewed with the patient both before discharge from the outpatient setting and again at home. This is to ensure accomplishment of the postoperative regimen at home, whether independently or with the assistance of a caregiver.
- Before discharge after surgery and at postoperative visits, patients should be instructed in the safe and proper instillation of medications.
- Assessment of the aforementioned factors and their potential impact on the patient's current and future health status is best allocated to health professionals, such as nurses, who are educated as well as trained to do extensive patient interviewing and physical, psychological, and home assessments. The patient living alone may need assessment for in-home support services, such as assistance with bathing, dressing, and preparing meals.
- When cataract patients who are considering surgery have the responsibility of being the primary caretaker for another individual, they should be referred to a home health/home care agency or family service agency for help in obtaining interim assistance in fulfilling that responsibility.
- The patient's emotional and/or spiritual needs should be assessed and the appropriate pastoral support arranged. The patient's quality of life is influenced by his or her ethnic, cultural, and religious philosophy about health and illness.
- The non-English-speaking patient population requires the efforts of interpreters to ensure that the information related is understood.

## Recommendations for Research

The panel makes the following recommendations for research.

- Supportive measures provided by home health nurses, visiting nurses, and social workers intuitively can be expected to have a favorable impact on the outcome. The need for and effectiveness of such measures should be studied.
- Research should be undertaken to determine if preoperative teaching, followed by a postoperative review, is sufficient patient education to eliminate noncompliance barriers to a successful postoperative rehabilitation.
- A risk assessment instrument should be developed to identify patients requiring expanded preoperative services and to evaluate the appropriateness of the home environment or the need for an alternative living arrangement postoperatively.
- Research should be funded to establish the cost-effective role of the ophthalmic registered nurse as an extension of the ophthalmologist in the community setting and home setting.
- Research should be directed toward the deficits surrounding care of the postoperative patient created by the performance of cataract surgery in the outpatient setting. The possible benefits of a team approach should be studied to develop a model for redesigning the collaborative effort that considers all aspects of patient needs.