# Guideline: Postoperative Care

From the patient's perspective, the period of postoperative care normally spans the interval from the conclusion of surgery until the goal of surgery is achieved by the provision of stable improved vision.

## Background

During the past 15 years, improvements in cataract surgery have greatly changed the postoperative management of the cataract patient. The widespread use of local anesthetic instead of general anesthetic, better wound-closure techniques, and earlier visual rehabilitation with intraocular lens (IOL) implants have led to an earlier return to everyday activities.

This earlier return to everyday activities and the success of the surgery have led to a reduced need for daily face-to-face care by the surgeon. Years ago, the cataract patient would remain in the hospital for up to 7 days after surgery, and care would be personally managed daily by the surgeon. A supportive nursing staff would attend the patient throughout the hospital stay. Today, the patient may be discharged from the outpatient surgical facility within an hour of surgery. The number of postoperative visits to the surgeon and access to nursing care are often, of necessity, limited. This diminishes the collaborative care mode, thereby reducing the level of care given the patient to self-care instructions given at the time of discharge. Preparation for and supervision of the postoperative period may be inadequate to meet the needs of many patients.

From the patient's perspective, the period of postoperative care normally spans the interval from the conclusion of surgery until the goal of surgery is achieved by the provision of stable improved vision. In the absence of complications, this usually occurs by 3 months after the surgery and coincides with the prescription of a final refractive correction. It also marks the point at which wound healing has advanced sufficiently that the integrity of the eyeball has been reestablished and many of the intraoperative and postoperative complications have been diagnosed and treated. If late complications develop, they may require treatment by the ophthalmologist who performed the surgery or by another suitable, competent ophthalmologist. This treatment may then extend beyond the postoperative period. (See also Chapter 3.)

## Literature Review

### Methods

The purpose of the literature review was to determine if there was evidence in the published literature to support or refute an association between the outcome of cataract surgery and the care provided in the postoperative period.

### Results

The literature search identified 36 potentially relevant articles. Upon further review, 15 of these articles were found to be relevant. These 15 articles underwent indepth content and methodologic review. The results of the literature review are as follows and are summarized in Evidence Tables M-1 to M-3 in Appendix M in the Guideline Report.

#### Question 1: Is there evidence to support or refute an association between outcome and usual frequency of postoperative visits?

In the articles reviewed on the relationship of postoperative care to cataract surgery outcome, there were no studies, review articles, or case reports that critically evaluated the frequency of postoperative care in relation to outcome variables. Four clinical trials did examine the influence of various treatment regimens on intraocular pressure, or IOP (Hollands, Drance, and Schulzer, 1987; Linn, Zimmerman, Nardin et al., 1989; Ruiz, Wilson, Musgrove et al., 1987; Tomoda, Tuberville, and Wood, 1984). These articles can be used to document the incidence of acute and potentially damaging increases in IOP during the first 24 hours after surgery, since they document a high frequency of untoward increases in IOP during the first 24-hour postoperative period; e.g., 33 percent of 18 controls showed IOP greater than 25 mmHg in Ruiz, Wilson, Musgrove et al. (1987). In summary, the IOP studies provide evidence that indicates a need to provide an evaluation of IOP during the first postoperative day.

One study (Laws, Watts, Kirby et al., 1989) documented the occurrence of bacterial contaminants obtained from the lid margin and fornix during the first postoperative day and showed some positive cultures. The study was not designed to indicate whether the bacteria were pathogens, contaminants, or part of the natural flora of the patient. It cannot be used to support or refute a claim that examination is necessary on the day following surgery.

A clinical trial (Sanders and Kraff, 1984) and an observational study (Carriker, Liebowitz, Nees et al., 1987) examined the influence of various treatments on postoperative inflammation during the first 3 weeks after cataract surgery. Although the clinical trial indicated a high percentage of patients with clinically unacceptable inflammatory responses (10-47 percent in this interval), the definition of "clinically unacceptable" was subjective, making this study difficult to interpret.

Evidence for the necessity to provide more long-term followup is indicated by an observational study (Jampel, Thompson, Baker et al., 1987) of 203 consecutive patients undergoing extracapsular cataract surgery. In this study, corneal curvature was not stable until 4-6 months after surgery. Therefore, any optical correction cannot be viewed as "final" until that approximate time period. As indicated within Evidence Table M-1 in Appendix M in the Guideline Report, however, the study was marred by flaws in methodology.

Three studies included in Evidence Table M-1 in Appendix M in the Guideline Report (Green and Peters, 1988; Kolder, 1982; Lichtenstein, 1986) provide only anecdotal information on followup schedules after cataract surgery, with no supportive evidence for the stated schedule.

In summary, there is quite convincing evidence that IOP needs to be monitored at about a 24-hour interval after surgery in order to detect patients who have potentially damaging IOP elevations. Most other complications that occur in this time period (e.g., endophthalmitis, wound dehiscence, wound leak, intraocular hemorrhage, dislocated lens) are too rare for a controlled study but can also be diagnosed. Evidence is far less abundant for postoperative evaluations at later points. Weak evidence indicates a need to evaluate the inflammatory response in operated eyes at 1-3 weeks after surgery. The refractive status of the operated eye likely does not stabilize until several months after surgery, so provision of a "final" optical correction for patients must await this time period of followup.

#### Question 2. Is there evidence to support or refute an association between outcome and content of visits? (Consider visual acuity, refraction IOP measurement, slit lamp examination, dilated fundus examination, medication administration, patient education.)

The remaining five articles in Evidence Table M-2 in Appendix M in the Guideline Report are reviews of potential complications of cataract surgery (Carver, 1987; Kolder, 1982; Lichtenstein, 1986; Masket, 1988; Mizuno and Miyake, 1987). They do not present new data on these questions.

In summary, the evidence that supports essential components of a postoperative visit to a health care provider depends largely on studies that document complications of cataract surgery. Since elevated IOP, inflammation, and corneal curvature changes are known complications, the literature includes studies that utilize tonometry, fluorophotometry, and keratometry, respectively, to evaluate the postoperative eye for these possible complications. This applies as well to fundus changes, such as cystoid macular edema, which can be diagnosed by various methods of examination, including ophthalmoscopy and fluorescein angiography.

#### Question 3: Is there information on cost and/or cost-benefit issues?

The literature contained no specific information on cost and/or cost-benefit issues in relation to postoperative management or outcome. The most that can be gleaned from the articles listed in Evidence Table M-3 in Appendix M in the Guideline Report are general statements about postoperative refractive alternatives (Carver, 1987; Young and Schwab, 1989).

A number of articles provide support for practices that affect cost directly, such as use of tonometry to measure IOP or use of steroid/antibiotic drop combinations in the postoperative period, but in no case are the cost or cost-benefit implications specifically discussed. The application of health economics science, therefore, seems to be missing from the literature on postoperative management and outcome after cataract surgery.

### Conclusions From the Literature Review

The literature review did not provide answers to any of the panel's questions dealing with postoperative care and outcome. However, direct evidence was provided about the importance of postoperative examination on day 1 and weaker evidence for the importance of the examination around the second or third week.

(See Appendix M in the Guideline Report for a full discussion of the literature review.)

## Conclusions of the Panel

The literature review did not provide answers to any of the specific questions raised. However, it did provide indirect evidence of the importance of measuring IOP and assessing the degree of postoperative inflammation, likelihood of infection, integrity of the wound, and proper location of the IOL in the first 24 hours following surgery. Although the literature does not critically evaluate postoperative care in relation to outcome variables, it presumes that postoperative care will be provided by a competent ophthalmologist who is aware of both common and rare complications of cataract surgery and is able to use the best available methods to diagnose these complications when they occur and when they are suspected. However, certain components of postoperative care can be delegated to one or more members of a team of appropriately trained professionals, including optometrists, community health nurses, and social workers.

## Recommendations for Care

The panel recognizes that the literature does not provide a scientific basis for establishing guidelines for the management of cataract patients during the postoperative period. Nevertheless, some recommendations were reached by consensus. The basic structure of this agreement is the American Academy of Ophthalmology Preferred Practice Pattern document, "Cataract in the Otherwise Healthy Adult Eye" (1989).

### Patient Education

The ophthalmologist who performs the surgery has an obligation to educate and instruct the patient regarding the following: appropriate signs or symptoms of possible complications, eye protection, activities, medications, required visits, and details for access to emergency care. The patient likewise has an obligation during the postoperative phase to follow the advice and instructions of the surgeon and to notify the surgeon promptly if problems occur.

### Patient's Condition at Discharge

Patients undergoing outpatient cataract surgery will normally be discharged from the facility to their home or to another accommodation that is conveniently close so that emergency care can be provided if needed. Criteria for discharge after ambulatory surgery include:

- Stable vital signs.
- Return to preoperative mental state.
- Absence of nausea.
- Absence of significant pain.
- Availability of an escort.
- Review, with the patient or escort, of postsurgical care until the first postoperative visit on the day following surgery, including relief of pain, activity level permitted, and access to emergency care if needed.
- Prearranged followup appointment.
- Written postoperative instructions.
- Suitable environment.
- Adequate home care support.

### Postoperative Hospitalization

Hospitalization after surgery may be unplanned or planned.

Operative complications of an ocular or medical nature are possible indications for unplanned postoperative hospitalization. Postoperative ocular complications can include hyphema, infection, wound dehiscence, endophthalmitis, uncontrolled elevated IOP, threatened or actual expulsive hemorrhage, retrobulbar hemorrhage, severe pain, or other ocular problems requiring immediate management or careful observation.

Medical complications can include cardiac instability, respiratory instability, a cerebrovascular episode, diabetes mellitus requiring immediate management, uncontrolled nausea or vomiting, acute urinary retention, acute psychiatric disorientation, or other medical conditions requiring immediate management or careful monitoring.

Indications for planned postoperative hospitalization are as follows:

- Medical conditions are present that require prolonged postoperative observation by a nurse or skilled personnel.
- Best correctable vision in the unoperated eye is 20/200 or worse.
- Patient is mentally debilitated, diagnosed as mentally ill, or functionally incapacitated so that a risk of injury exists in the immediate postoperative period.
- Physical disability prevents satisfactory immediate postoperative care.

### Postoperative Visits

The frequency of examination during the postoperative period is predicated on the need to:

- Diagnose and provide the most efficient treatment for complications when they arise.
- Provide appropriate postoperative care as healing proceeds.
- Educate and support the patient during the postoperative period.

Fortunately, serious complications occur infrequently with modern cataract surgery (see Anesthesia, Chapter 5). However, they occur unpredictably and when untreated may have a devastating effect on the outcome of surgery. In order to minimize the risk that such complications will go unrecognized and, therefore, untreated, a schedule of visits is recommended by the panel based on the following requirements:

- The earliest practical assessment of the effects of the surgery.
- The diagnosis and treatment of immediate complications of surgery.
- The prompt diagnosis of other complications that could be potentially devastating to vision, particularly infection and glaucoma. Both of these complications may occur at any time during the postoperative period. Although the most acute bacterial infections tend to present within the first few days of surgery, less virulent but still potentially devastating infections with other bacteria and fungi may develop in the succeeding weeks and months.

The frequency of normal followup for a patient without signs or symptoms of possible complications is:

- First visit: day after surgery.
- Second visit: approximately 1 week after surgery.
- Third visit: approximately 3 weeks after surgery.
- Fourth visit: approximately 6-8 weeks after surgery.

More frequent postoperative visits are indicated if unusual findings or complications occur.

### Postoperative Examinations

The components of postoperative examinations include the following:

- Visual acuity each visit.
- IOP measurement each visit.
- External examination each visit.
- Slit lamp examination each visit.
- Patient counseling and education each visit, unless the patient's condition does not allow it. (This should include information about progress toward healing, medication instructions, level of activity permitted, symptoms requiring emergency care, and access to emergency care.)
- Ophthalmoscopy. (A dilated fundus examination to include the peripheral retina should be done at least once during this postoperative period.)

The timing and frequency of refraction will depend on patient needs, the amount of astigmatism, and the stability of the measurement. Sutures may be cut or removed by the ophthalmologist for the reduction of astigmatism. Usually, optical correction can be prescribed 6-12 weeks after surgery.

### Long-Term Followup

Patients should be informed of the need for periodic eye examinations and of the possible need for YAG capsulotomy if a posterior capsular opacification develops.

## Recommendations for Research

Research regarding the suitability of various practice patterns of postoperative care should be promoted. In particular, research should be directed to determine whether some of the new practice patterns encouraged by changes in legislation and reimbursement are influencing the quality of care.