# Guideline: Treatment

Functional rehabilitation as a result of visual improvement is possible in the vast majority of patients and should be the goal at each stage of treatment.

## Nonsurgical Management

For the patient developing cataracts, nonsurgical methods of management include patient education and reassurance about the cause of visual disability and the prognosis. In the developmental stage of nuclear sclerosis, a common type of cataract, myopia is induced, and changing the spectacle lens prescription will often improve vision. The use of strong bifocals, magnification, appropriate lighting, and other visual aids often satisfies the new vision requirements as the cataract progresses. Dilation of the pupil may allow the patient to view around the central posterior subcapsular (PSC) cataract. During this period of early cataract development, such measures may be successful for many patients in meeting their visual needs without recourse to surgery. However, the glare experience from such a cataract may be unacceptable, particularly when the intensity of ambient light is high or when the individual is facing high-intensity light, as in night driving.

## Surgical Management

No test adequately describes the effect of cataract on the patient's visual status or functional ability. The decision to perform cataract surgery cannot and should not be made on the measurement of Snellen visual acuity alone; the likely degree of visual improvement and its impact on the quality of life must be weighed against the risk and cost of surgery. Although not a definitive measure of visual dysfunction, simple Snellen acuity is the most universally used index of visual function. Other, newer techniques for evaluating visual function are under investigation, but their reliability and standardization have yet to be established (see Chapter 4 and Adamsons, Rubin, Vitale et al., 1992; Cink and Sutphin, 1992, articles published after the cutoff date for the systematic literature review). Until reliability and standardization are established, clinical judgment combined with Snellen acuity remains the best general guide to the appropriateness of surgery. However, it is recognized that an individual's particular functional and visual needs, environment, and risks may vary widely and must be taken into account.

## Indications for Surgery

The purpose of cataract surgery is to reduce and ideally to eliminate or remove functional impairment caused by the presence of a cataract. Only in unusual circumstances is cataract surgery performed for other reasons. How the patient and the ophthalmologist come to the decision to proceed with cataract surgery is the subject of this part of the guideline.

### Literature Review

#### Methods.

The purpose of the review was to identify the appropriate indications and contraindications for cataract surgery. (For a full description of the literature review, see Appendix H in the Guideline Report.)

#### Results.

The questions identified by the panel are as follows.

1. Is there evidence to support or refute an association between outcome, with and without surgery, and specific indications for surgery?

2. Is there evidence regarding the outcome of surgery in patients whose other eye is legally blind?

3. Is there information on cost and/or cost-benefit issues?

The 48 papers selected were reviewed. None of these papers addressed the questions specified by the panel.

### Conclusions

In most circumstances, cataract surgery is considered a nonemergency procedure. It is indicated when the cataract reduces visual function to a level that interferes with everyday activities of the patient. The severity of the interference can range from simple symptoms of glare disability to reduced ability to perform recreational activities and difficulty with reading, driving, employment, and performing other everyday activities.

The appropriateness of cataract surgery at each level of disability depends on the complete assessment of the overall visual function and the needs of the patient as well as adequate informed consent. Surgery for cataract is considered when medical, optical, and environmental measures have proved inadequate for the patient's visual requirements. The patient should make the decision to proceed with surgery on the basis of the ophthalmologist's recommendation and after considering subjective, objective, and educational criteria. However, the indication for surgery is founded on the patient's requirement for better vision and the patient's reasons for undergoing surgery. In almost all circumstances, surgery should not be performed solely because the cataract is present.

The ultimate decision regarding the desirability and timing of cataract surgery is determined by the patient and the ophthalmologist who is to perform the surgery. After a complete evaluation, the ophthalmologist confirms the subjective and objective findings of vision reduction related to a cataract.

Unfortunately, as discussed in Chapter 4, there are no objective, stand-alone measures of functional impairment due to cataract that might serve as precise indications for cataract surgery. The development of such measures is a matter of high priority.

### Recommendations for Care

The search of the literature did not reveal any information helpful in elucidating precise indications for surgery. Thus, pending the results from future research, the panel recommends the adoption of the following guidelines based on the Preferred Practice Pattern, "Cataract in the Otherwise Healthy Adult Eye," produced by the American Academy of Ophthalmology (1989). Although it is principally directed toward the elective decision to undergo surgery, it also considers those circumstances in which cataract surgery is indicated because the health of the eye or the health of the person is endangered. The panel recognizes that scientific evidence is lacking from the published literature to support the validity of these guidelines. Nevertheless, the Preferred Practice Pattern, which was developed by an exhaustive consensus method, has been available for 3 years and has not been substantially challenged.

The indications for surgery are considered for various levels of visual impairment. A cutoff of Snellen acuity of 20/50 or worse is based on common State laws requiring better vision for drivers of motor vehicles.

#### Visual Disability With a Snellen Acuity of 20/50 or Worse.

Cataract surgery is justified and appropriate when the subjective, objective, and educational criteria are met.

##### Subjective

The subjective criterion in this case is that the ability to carry out needed or desired activities is impaired. The patient's decision depends on his or her assessment of visual disability (e.g., impact on driving, reading, watching television, and special occupational or avocational needs) and perception of the impact of the disability on lifestyle (e.g., loss of independence, loss of income).

##### Objective

The objective criterion is based on the best level of visual acuity. The best correctable visual acuity in the affected eye is 20/50 (Snellen) or worse and the cataract is responsible for this. The patient's medical and mental health should permit surgery to be performed safely.

##### Educational

The patient should be educated about the risks and benefits of cataract surgery, including treatment alternatives. The patient determines if the expected reduction in the disability outweighs the potential risk, cost, and inconvenience of surgery.

#### Visual Disability With a Snellen Acuity of 20/40 or Better.

Cataract surgery is justified and appropriate when all of the following criteria are met.

##### Subjective

The subjective criterion for justifying surgery for this level of disability is also that the ability to carry out needed or desired activities is impaired. There are three aspects of this to consider:

- The patient's own assessment of visual disability (e.g., impact on driving, viewing television, and special occupational or avocational needs) and disability at near (e.g., reading, occupational activities requiring near vision).
- The patient's perception of the impact of the disability due to the cataract on his or her lifestyle.
- The patient's complaints of disabling glare. Occasionally, patients with cataract present with the complaint of disabling glare. These patients will often see more poorly in daylight conditions, so their visual complaints will be inconsistent with the visual acuity measured in a darkened room. When this appears to be the case, the assessment of visual function under conditions of ambient sunlight will often reveal the existence of this functional complaint and the reasons for it. The differences between measured acuity in a darkened room (and high-contrast chart) and that with ambient light producing glare and reduction of functional acuity need to be documented. When such a verifiable, reproducible loss of vision can be documented, mimicking the patient's complaints, the patient can be considered for cataract surgery. The application of glare testing and contrast sensitivity testing is discussed in Chapter 4.

As a general rule, the better the Snellen acuity is, the greater the need is for verification and documentation of functional disability. When visual acuity is 20/40 or better, the risk relative to the potential benefit of surgery becomes even more significant. Decreased vision and function may be documented for any of the following reasons:

- Visual disability fluctuates as a result of environmental factors (e.g., effects of glare, such as lights of oncoming cars or dim illumination).
- The patient complains of monocular diplopia or polyopia.
- Visual disparity exists between the two eyes.
- The patient needs but cannot obtain an unrestricted driving license.

##### Objective

The objective criterion is also based on the level of visual acuity. The best correctable visual acuity is 20/40 or better (Snellen) in the affected eye. The eye examination confirms that cataract is the limiting factor for improving visual function when other factors do not preclude improvement following surgery. The patient's medical and mental health should permit surgery to be performed safely.

##### Educational

The patient should be educated about the risks and benefits of cataract surgery and alternatives to surgery. In the patient with a visual acuity that is 20/40 or better, the risk of surgery relative to the expected benefit should be reemphasized to the patient. The patient determines if the expected improvement of the disability outweighs the potential risk, cost, and inconvenience of surgery.

#### Visual Disability Due to Cataract in the One-eyed Patient.

(See also this chapter's section on second eye surgery.) A one-eyed patient is defined as one who has permanent legal blindness in one eye.

The ophthalmologist who will perform the surgery has the obligation to inform and educate the patient as to the risk of total blindness when the potential benefits of cataract surgery are considered. The same criteria apply for both levels of visual disability. The worse the vision is in the fellow eye, the greater the need is for caution when cataract surgery is considered.

#### Other Indications for Cataract Removal

There are two other indications for cataract removal:

- Lens-induced disease.
- The need to visualize the fundus.

As documented in the published literature, cataract removal may be necessary in the presence of lens-induced diseases (e.g., phacomorphic glaucoma, phacolytic glaucoma). Because of sight-threatening and eye-threatening complications, the need for cataract extraction may be urgent.

It is necessary to visualize the fundus to manage adequately ocular conditions that would otherwise lead to worse or permanent visual loss in an eye that has the potential for sight (e.g., the patient has diabetes, with significant risk of reduced visual acuity from diabetic retinopathy requiring management through visualization for diagnosis or clear media laser therapy) or when other special investigations demonstrate intraocular pathology for which further attention is important and clear media are required.

### Recommendations for Research

The panel recommends that research be directed toward a better understanding of functional impairment due to cataract to elucidate more precisely the appropriate indications for cataract surgery.

## Contraindications for Surgery

Surgery should not be performed solely to improve vision under the following circumstances:

- The patient does not desire surgery.
- Glasses or visual aids provide satisfactory functional vision.
- The patient's lifestyle is not compromised.
- The patient is medically unfit.

## Preoperative Medical Evaluation

### Background

Most patients undergoing cataract surgery are elderly persons, a population with a high prevalence of concurrent medical problems such as coronary artery disease, cerebrovascular disease, hypertension, diabetes mellitus, dementia, arrhythmias, chronic obstructive pulmonary disease, alcoholism, thromboembolic disease requiring anticoagulant therapy, and nutritional problems. In addition, these patients often have unique and commonly dysfunctional problems of aging, including situational difficulties and other problems, such as arthritis, as well as psychosocial, economic, and nutritional difficulties. Functional problems and their causes (often multiple and complex), defined as difficulties that interfere with daily routines, are often unappreciated when conventional histories and physical examinations are done. This part of the guideline addresses the appropriate preoperative medical and general evaluation of patients undergoing cataract surgery.

### Literature Review

#### Methods.

A literature review was performed to identify articles with information on the preoperative medical and general evaluation of patients undergoing cataract surgery. In addition to the literature found in the National Library of Medicine search concerning preoperative testing and evaluation, the relevant literature relating to preventive health measures, especially in the elderly, and some applicable literature concerning nonophthalmologic surgery were reviewed in preparation of the guideline. (For a full description of the literature review, see Appendix I in the Guideline Report.)

#### Results.

All the articles identified from the National Library of Medicine literature search, reviewers, and other interested parties have serious methodologic flaws. Eight (Applegate, Miller, Elam et al., 1987; Backer, Tinker, Robertson et al., 1980; Fisher and Cunningham, 1985; Hardesty, 1989; Maltzman, Cinotti, and Calderone, 1981; McMahan, 1988; Quigley, 1974; Stone, Kline, and Sklar, 1985) provided data on the value of the medical preoperative evaluation of patients with cataract. None addressed cost-benefit issues. Most are retrospective studies of patient cohorts who had undergone cataract surgery and thus were sufficiently healthy to have tolerated it. None mentioned the findings on health status of patients who had not undergone surgery. There is, thus, scant published information from which conclusions can be drawn and on which irrefutable recommendations about the preoperative medical evaluation can be based.

##### Question 1: Is there evidence to support or refute a specific association between short-term medical outcome in the postoperative period and the preoperative medical evaluation of the patient (physical examination, electrocardiogram, chest x ray, complete blood count, other)?

Comprehensive recommendations about preventive health screening were made by the U.S. Preventive Services Task Force (1989), the American College of Physicians (1981 and 1987), the American Cancer Society (1988), the American Geriatrics Society (1989), the National Institutes of Health (National Cholesterol Education Program, 1988; National Institutes of Health, 1988; 1988 Joint National Committee, 1988), and the Canadian Task Force on the Periodic Health Examination (1989 and 1991). These preventive care guidelines were recently summarized in a comprehensive paper by Hayward and associates (Hayward, Steinberg, Ford et al., 1991).

There appears to be substantial variability among different institutions in the preoperative medical evaluation of cataract patients. The author of one textbook recommends that a full battery of screening tests be obtained (e.g., complete blood count, electrolytes, renal function test, urinalysis, electrocardiogram, and chest x ray) because of the advanced age and multiple medical problems of these patients (Hardesty, 1989). Others advocate reducing the routine preoperative testing and report no significant harm in making such reductions in patients undergoing a variety of surgical procedures, all of which have a greater risk of complications than cataract surgery (Blery, Charpak, Szatan et al., 1986; Kaplan, Boeckmann, Roizen et al., 1982; Kaplan, Sheiner, Boeckmann et al., 1985; Lawrence, Gafni, and Gross, 1989; Roizen, 1988). In particular, the usefulness of a routine preoperative urinalysis (Lawrence, Gafni, and Gross, 1989) and chest x ray (Charpole, Blery, Chastang et al., 1988; Roberts, Fowkes, Ennis et al., 1983; Rucker, Frye, and Staten, 1983) has been questioned, and the benefit of preoperative pulmonary function testing seems to be restricted to a very small group of surgical patients that does not include cataract surgery patients (American College of Physicians, 1990; Zibrack, O'Donnell, and Marton, 1990).

Concurrent medical problems are especially common in patients undergoing cataract surgery. A retrospective study by Maltzman and associates (Maltzman, Cinotti, and Calderone, 1981) of 200 patients who underwent cataract surgery found that only 51 patients (25.5 percent) had no disorders other than cataracts. Previously known chronic ailments were present in 137 (68.5 percent), and 44 (22 percent) had 58 newly discovered disorders. The medical ailments present in the patients included cardiac disorders (7 percent), diabetes mellitus (4 percent), hypertension (3.5 percent), pulmonary disease (3.5 percent), anemia (2.5 percent), inguinal hernia (2 percent), hepatomegaly (2 percent), and other abnormalities (venous insufficiency, urinary tract infection, electrolyte imbalance in 4.5 percent). Each of the five preoperative tests (chemistry profile, complete blood count, urinalysis, x ray, electrocardiogram) performed on this group of patients appeared equally important in uncovering new disease. The authors believed that none of the preoperative medical tests could have been eliminated to reduce the cost of testing without missing some of the medical disorders. In addition to being retrospective, the study has several methodologic flaws that weaken its scientific strength. A number of patients were excluded from the study because threatening preadmission findings caused their surgery to be canceled, thus biasing the study toward making preadmission testing appear less important than it actually was in detecting unknown disease. The importance of preoperative testing is actually understated by the data in this study. The age of the patients in this study was not mentioned.

In another retrospective study, 100 consecutive patients who averaged 75 years of age and who had undergone cataract extraction in the hospital were retrospectively reviewed (Fisher and Cunningham, 1985). Laboratory investigation included a complete blood count, chemistry profile, urinalysis, chest x ray, electrocardiogram, and other tests as indicated by the history and physical examination. One or more significant preexisting medical conditions were found in 84 percent of the patients. Conditions included hypertension (47 percent), diabetes mellitus (16 percent), congestive heart failure (10 percent), and significant pulmonary disease, including chronic obstructive pulmonary disease, chronic bronchitis, and interstitial fibrosis (7 percent). Significant atherosclerosis or arteriosclerotic heart disease, defined as previous myocardial infarction, angina, peripheral vascular insufficiency, occlusive carotid disease, atherosclerotic valvular disease, or a history of transient ischemic attacks or strokes, was found in 38 percent of the patients. The authors of this study believe that all patients undergoing cataract extraction should have a thorough preoperative medical evaluation. Many patients (78 percent) were taking one or more medications, including coumadin (4 percent). In addition to being retrospective, the study has several methodologic flaws that weaken its scientific strength. Patients excluded from the study because preadmission findings caused their surgery to be canceled were not included, thus biasing the study toward making preadmission testing appear less important than it actually was in detecting unknown disease. The importance of preoperative testing is thus also understated by the data in this study.

A study by Blery and associates (Blery, Charpak, Szatan et al., 1986) from a teaching hospital in France is informative in this regard. Selective ordering of 13 preoperative tests (blood typing, antibody screen, hemoglobin, prothrombin time, partial thromboplastin time, bleeding time, platelet count, electrolytes, creatinine, blood-urea-nitrogen (BUN), glucose, chest x rays, and electrocardiogram) was studied in 3,866 consecutive patients undergoing surgery under general or regional (but not local) anesthesia over a 1-year period between 1983 and 1984. Almost half the patients underwent minor surgical procedures defined as potentially bloodless operations, most of which were done on an elective basis. Although cataract surgery would fall into this category, the study did not specifically address cataract extraction. Preoperative testing was done according to a protocol that accounted for the patient's clinical status and type of surgery. Routine testing was not done in patients undergoing minor surgery unless they were age 40 and over, had associated conditions, or were taking medications. For instance, an electrocardiogram was done routinely in those age 40 and over, and electrolytes, creatinine, and BUN determinations were routinely done in those over age 70. Patients with cardiovascular or pulmonary disease had chest x rays and electrocardiograms, regardless of their age, and patients with diabetes mellitus all had renal function, electrolytes, and glucose determinations. This strategy resulted in an average of about four tests for each patient in the entire group. A total of 140 patients (8 percent) in the minor surgery group experienced preoperative or postoperative morbidity, and two died after surgery. The possible value of tests that were omitted was assessed in light of events that occurred during and after surgery. The authors concluded that 0.4 percent of nonordered tests would have been potentially useful according to predetermined computerized criteria, and only 0.2 percent would actually have predicted an adverse outcome according to the opinion of the anesthesiologists participating in the study. This study has several methodologic flaws, and its generalization to cataract patients is also questionable. The study actually comprised a series of judgments resulting in very different testing of a broad variety of patients with disparate diseases. Despite the large number of patients in this study, its statistical power is uncertain, since a number of patient populations with very different characteristics were studied. For example, the level of illness was not systematically addressed. In addition, the study's design may have biased the results to favor the conclusions that were reached by the authors; the idea that computerized criteria can be established to identify laboratory tests that will predict an adverse outcome is a unique idea that itself requires validation. The anesthesiologists were not blinded to the patient's adverse outcome when they made a judgment about the laboratory testing, which may also have biased the results.

###### Perioperative Management of Selected Common Medical Problems

Most cataract patients are elderly, with a high prevalence of conditions associated with aging. In addition, elderly patients often take one or more potent medicines. Despite these concurrent problems, the risk of this short, very limited surgical procedure is low. The perioperative mortality of ophthalmic surgery patients overall is only 0.16 percent, and for cataract patients, it is 0.1-0.2 percent (Quigley, 1974). The incidence of serious medical complications such as myocardial infarction associated with ophthalmologic surgery under local anesthesia is less than 1 percent, even in patients with a past history of myocardial infarction.

Although the risk of serious medical complications is quite low in cataract surgery patients, concurrent medical problems frequently cause concern among ophthalmologists, anesthesiologists, internists, and other physicians involved in the management of these patients. Such concerns may lead to additional pre-, intra- and postoperative interventions that may be associated with considerable cost and uncertain benefit. To date, optimal perioperative management of medical problems has not been defined for cataract patients specifically. Therefore, it is likely that a great deal of variation exists in current practice patterns regarding the perioperative medical management of cataract patients.

Anticoagulant drugs being taken for thromboembolic, cardiovascular, or neurologic disorders pose a special problem. The literature reflects conflicting practices during cataract surgery concerning patients taking anticoagulant drugs. A recent survey (Stone, Kline and Sklar, 1985) of 135 cataract surgeons indicated that 75 percent of the respondents withheld anticoagulation during the perioperative period, which resulted in two deaths from strokes, two additional strokes, one transient ischemic attack, a cerebral embolism in a patient with an artificial valve, a pulmonary embolus, and an episode of deep-vein thrombosis. This retrospective survey does not provide enough data about the patients, their level of disease, or how the decision was made to discontinue anticoagulant drugs to permit a critical analysis of the conclusion. Another study (McMahan, 1988) prospectively compared the outcome of 22 patients undergoing intraocular lens (IOL) implantation who were receiving anticoagulants with age-matched patients (controls) who were not receiving these drugs. After continuing anticoagulation through the surgical and postoperative period, no patient experienced clinically significant bleeding that interfered with vision. There were no retrobulbar, vitreous, or retinal hemorrhages and no elevated pressures in any anticoagulated or control patient. On the basis of these limited data, it appears that anticoagulation does not pose a substantial risk for seriously complicating ophthalmic surgery, whereas discontinuing these drugs may impart some increased risk for new thrombotic events in the patient with preexisting cardiovascular, cerebrovascular, or thromboembolic disease. The selection of controls in this study was weak, since they were matched with patients only for age and not other characteristics, such as underlying major illnesses. In addition, the study is flawed by the very small number of patients, which makes the likelihood of a type 2 error very high.

Myocardial reinfarction in the course of cataract surgery is of particular concern in the elderly patient with a past history of myocardial infarction. A retrospective study (Backer, Tinker, Robertson et al., 1980) of myocardial reinfarction after local anesthesia for ophthalmic surgery found no postoperative reinfarction or death in 195 patients who underwent 288 separate operations. The 0 percent reinfarction rate was significantly less than the 6.1 percent reinfarction rate previously reported from the same institution for 587 operations on patients with documented preoperative myocardial infarction who had general or major regional anesthesia for nonophthalmic surgery. Thus, on the basis of these limited data, it appears that ophthalmic surgery under local anesthesia and/or retrobulbar block does not pose special risks for reinfarction in the patient with a preoperative myocardial infarction. This study's major weakness is that it selectively reports only on patients on whom surgery was done, omitting those who might have been rejected for surgery because of serious cardiac symptoms or signs or because of ominous laboratory tests. For instance, if patients with congestive heart failure or severe angina undergo surgery, the results might be different than if they had been rejected as unsuitable surgical candidates.

###### Preoperative Evaluation of the Elderly Patient

The majority of patients undergoing cataract surgery are elderly persons who not only have a high prevalence of multiple medical problems, but also have unique problems of aging that commonly affect their ability to function. Functional problems, defined as difficulties that interfere with daily routines, are often unappreciated when conventional histories and physical examinations are done. Functional assessment, therefore, is an integral part of geriatric care (American College of Physicians, Health and Public Policy Committee, 1988; Williams, 1990). Its importance was underscored by the Consensus Development Conference at the National Institutes of Health (1988), which stated that comprehensive geriatric assessment is effective in improving the quality of ongoing care.

Although most elderly noninstitutionalized adults are functionally competent, the percentage who need help doing everyday activities doubles with each successive decade up to age 84 and triples between ages 85 and 94 (Feller, 1983). In addition to visual dysfunction, elderly persons often have other equally severe and unrecognized functional problems resulting from hearing disorders, difficulty with arm and leg function, urinary incontinence, depression, dementia, environmental hazards, and inadequate financial and social support systems. Although there is general agreement that functional assessment is most useful when a standard, systematic approach is used to measure and record observations, there is a general lack of consensus on the best way to perform these evaluations (Williams, 1990).

One study (Applegate, Miller, Elam et al., 1987) prospectively examined the impact of cataract surgery on the functional status of 293 elderly patients undergoing cataract surgery. Patient function was evaluated by both subjective measures (everyday activities and self-report of vision-dependent activities) and objective measures (timed manual performance tests and mental status tests). With marked improvement in visual acuity, modest positive changes occurred in self-reported everyday activities and vision-dependent activities; the most marked changes occurred in objective measures of function. Mental status improved significantly 1 year after surgery, and timed manual performance improved dramatically at 4 months and 1 year. This study is sound methodologically but does not address the issue of preoperative medical testing of cataract patients. Cataract surgery was associated with better vision and improved functional status in most patients by 4 months after surgery and was maintained 1 year later.

The patient's perception of disability and self-assessment of impairment are extremely important in evaluating the impact of therapy. A new approach to assessing functional disability was described by Tugwell and associates (Tugwell, Bombardier, Buchanan et al., 1987), who devised an instrument that has the potential to detect small, clinically important changes in function. These authors developed a new patient preference questionnaire for assessing disability that focuses only on those activities directly affected by the disability and judged to be important by the patient. This study is sound methodologically but does not address the issue of preoperative medical testing of cataract patients.

The American College of Physicians recently advocated incorporating functional status measurement into routine clinical practice (American College of Physicians, Health and Public Policy Committee, 1988). The College commissioned a group of investigators to identify the important areas in which elderly persons who are not acutely ill should be screened for functional disabilities and to develop a simple, practical, and sensible approach to the screening assessment. Lachs and associates (Lachs, Feinstein, Cooney et al., 1990) devised such an instrument. After a careful literature review, Lachs and coworkers concluded that most published instruments were impractical because they are too lengthy, require special equipment, or are not targeted to older populations. With the assistance of a panel of expert geriatricians and general internists, they developed a short, simple approach that can be used by primary health care providers to screen the functional status of elderly patients routinely. The instrument focuses on a limited number of target areas that are commonly dysfunctional but often unappreciated in the elderly when conventional histories and physical examinations are done. The instrument uses carefully selected tests of vision, hearing, arm and leg function, urinary incontinence, nutrition, mental status, depression, basic everyday activities (a term that refers to the abilities needed for independent self-maintenance in the basic functions of bathing, eating, dressing, toileting, transferring, and walking), and instrumental everyday activities (a term often used for higher levels of independent function such as cooking, shopping, and light housework) and explores potential environmental hazards and social support systems. Brief questions and easily observed tasks are used to obtain information in a short time. One of its targets is the home environment. It explores the most troublesome obstacles in mobility for elderly patients living at home: the stairs, both inside and outside. Patients are asked about potential hazards inside the home with rugs, bathtubs, and lighting. It also asks about the social support network in which the patient functions and examines the availability of care to be anticipated during a transient illness such as the postoperative period. The home environment and anticipated support network are especially important issues for patients undergoing cataract surgery. This instrument requires no special equipment and can be done by a nurse, physician, or other trained health care provider. It also suggests appropriate interventions.

Cultural, ethnic, and spiritual values should be noted, along with the individual's own assessment of the quality of life (Maltzman, Cinotti, and Calderone, 1981). The clinician should evaluate the economic resources of the elderly person, since this often determines access to medical and personal care and influences options for living arrangements.

##### Question 2: Is there evidence to support or refute an association between nonmedical evaluation and preparation of the patient and outcomes? (Issues researched include psychosocial issues, patient education, patient preparation, family preparation, and home environment.)

##### Question 3: Is there information on cost and/or cost-benefit issues?

No articles were found addressing these questions.

### Conclusions of the Panel

The evidence in the published literature is sparse. The panel reached the following conclusions by consensus:

- The preoperative medical examination and appropriate testing should be done in all patients undergoing cataract surgery, whether the surgery is done in the hospital or elsewhere and regardless of the type of anesthesia to be used.
- Preoperative medical management should be guided by the patient's age, the presence of concurrent medical illnesses, the patient's use of medicine, and the patient's relative proximity to the location where surgery is performed.
- General preventive health measures (e.g., for hypertension, diabetes, smoking, and obesity) are suggested for all, including patients who otherwise may have infrequent encounters with the health care system. The panel believes that patients have the right to know what preventive measures are effective and appropriate in these circumstances, although they may choose to not take advantage of them.
- The preoperative medical evaluation should include screening for functional disability. Elderly patients should receive special screening of functional status, and particular attention should be given to the socioeconomic problems imposed by aging. This recommendation is in keeping with the panel's stated ultimate goal of improving the patients' overall long-term health and functional ability and the maintenance of autonomy.
- The panel agreed that the patient (or the patient and the ophthalmologist) can choose to have the preoperative medical evaluation for cataract surgery performed by a generalist or an appropriate subspecialist. This should be considered a separate service from the preoperative ophthalmologic evaluation in regard to the global surgery concept for cataract surgery.
- Areas of special importance to the individual such as cultural ethics and spiritual values should be taken into consideration before surgery, along with the individual's own assessment of the quality of life, for optimal preparation of the patient for surgery and recovery.
- The economic resources of the elderly person should be evaluated before surgery, since this often determines access to medical and personal care and influences options for living arrangements.
- Although the data are sparse, anticoagulation does not appear to pose a substantial risk for seriously complicating ophthalmic surgery, whereas discontinuing these drugs may impart some increased risk for new thrombotic events in the patient with preexisting cardiovascular, cerebrovascular, or thromboembolic disease.

In light of the sparse published literature available on this topic, the panel is unable to make explicit recommendations regarding the extent of the general medical evaluation and testing that should be done prior to cataract surgery. The panel recognizes, however, that this is an issue that cuts across the whole field of elective surgery and patient care.

Accordingly, the panel recommends that AHCPR develop guidelines for preoperative general medical evaluation and general medical testing of patients undergoing nonemergency surgery, including cataract surgery. Until such guidelines are established, the panel agreed that it should adopt a common sense approach to preoperative evaluation that would be sensitive to the medical judgment of a prudent physician evaluating an individual patient. Unfortunately, no consensus exists concerning the explicit goal of the preoperative medical evaluation of the patient scheduled for cataract surgery. However, the Preventive Services Task Force (1989) has recommended routine preventive measures for use in primary care settings that may be applicable to patients undergoing surgical procedures who do not ordinarily receive routine care. The preoperative medical evaluation can either be narrowly viewed as an occasion to evaluate the patient's health solely as it pertains to cataract surgery or be approached in the broader context of a unique opportunity to evaluate the patient fully and to diagnose potentially serious health, functional, and social problems unrelated to cataract surgery. The broader view is consistent with an ultimate goal of improving the overall long-term health and well-being of patients undergoing cataract surgery, instead of restricting the focus to improving vision. The panel favored the broader view but acknowledged that preventive health screening is a secondary issue that was not part of the panel's charge.

### Recommendations for Research

Preoperative testing of cataract patients requires further study. Prospective studies should be designed and nationally funded to test the cost effectiveness of complete medical evaluation insofar as it prevents untoward intraoperative and postoperative events, uncovers previously unrecognized and treatable disease, and effectively disseminates preventive health measures.

## Anesthesia

Anesthesia for cataract surgery can be either general or local.

### Background

The choice and management of anesthesia technique may have a direct effect on the success of cataract surgical outcome. Many cataract patients are elderly, with multiple medical problems, particularly pulmonary and circulatory, and thus are at increased risk for morbidity during the perioperative period.

Anesthesia decisions that may influence outcome include the choice of general anesthesia vs. regional anesthesia with sedation and the choice from a variety of retrobulbar or peribulbar local anesthesia techniques available. The training and experience of the practitioner may influence the results and complication rates.

Finally, consideration must be given to the costs and benefits of various anesthetic management plans.

### Literature Review

#### Methods.

The purpose of the literature review was to identify and review those articles that might provide a sound clinical and scientific basis for recommendations for anesthesia management of the cataract patient. The literature review was limited to recent (1975-90) articles that addressed nine specific search questions relating to anesthesia and cataract surgery. (For a full description of the literature review process, see Appendix J in the Guideline Report.)

#### Results.

A preliminary literature search identified 87 potentially relevant articles. Seven additional articles were identified from various sources. Of these 94 articles identified, only 9 were found to be relevant to the questions addressed by the panel. These nine articles underwent indepth methodologic and content review. The results of the literature review are as follows and are summarized in Attachment 7 at the end of this document.

##### Question 1. Is there evidence to support or refute an association between visual outcome of cataract surgery and the choice of general vs. local anesthesia?

##### Question 2: Is there evidence to support or refute an association between visual outcome of cataract surgery and the choice of local anesthesia, retrobulbar vs. peribulbar?

##### Question 3: Is there evidence to support or refute an association between visual outcome of cataract surgery and the identity and credentials of the individual monitoring the patient?

##### Question 4: Is there evidence to support or refute an association between visual outcome of cataract surgery and the identity and credentials of the individual administering retrobulbar injection? (Consider anesthesiologist, nurse anesthetist, ophthalmologist, technician, other.)

No evidence was found in the literature addressing these questions.

##### Question 5: Is there evidence to support or refute an association between anesthesia morbidity and choice of general vs. local anesthesia?

One article (Karhunen and Orko, 1981) found that nausea and vomiting may be less likely after local than general anesthesia. This article had significant methodologic flaws.

##### Question 6: Is there evidence to support or refute an association between anesthesia morbidity and choice of local anesthesia, retrobulbar vs. peribulbar?

Three articles (Hamilton, Gimbel, and Strunin, 1988; Weiss and Deichman, 1989; Whitsett, Balyeat, and McClure, 1990) appeared to indicate that a peribulbar technique can be as effective as retrobulbar, but with fewer complications. Another article (Whittpen, Rapoza, Sternberg et al., 1986) suggested that patients receiving 4-percent lidocaine by retrobulbar injection were at greater risk of respiratory arrest than patients receiving 2-percent preparation. All studies were flawed by general methodologic deficiencies that made the conclusions difficult to interpret, though they were intuitively appealing.

##### Question 7: Is there evidence to support or refute an association between anesthesia morbidity and the identity and credentials of the individual monitoring the patient? (Consider anesthesiologist, nurse anesthetist, operating ophthalmologist, other.)

One article (Meyers, 1979) suggested that there was an increased incidence of severe cardiovascular complications in unmonitored patients. A number of methodologic flaws in this retrospective evaluation of a clinical series rendered the study's conclusions uncertain and difficult to interpret.

##### Question 8: Is there evidence to support or refute an association between anesthesia morbidity and the identity and credentials of the individual administering retrobulbar or peribulbar injection? (Consider anesthesiologist, nurse anesthetist, ophthalmologist, technician, other.)

##### Question 9: Is there information on cost and/or cost-benefit issues?

No articles were found in the literature addressing these questions.

### Conclusions From the Literature Review

Of the 94 articles identified by the National Library of Medicine computer search and other sources, only 9 met the search criteria and were further considered by content and methodologic reviewers for detailed analysis. Results of the review of these articles revealed that only three were randomized controlled trials. The remainder were either uncontrolled trials or clinical series. There were no well-designed prospective studies that compared general anesthesia vs. local anesthesia and anesthesia morbidity. No studies associated morbidity with the identity of the person monitoring or administering the local anesthesia injection. Two articles mentioned cost effectiveness in passing, but there was no study specifically analyzing in detail the costs and benefits of general vs. local anesthesia.

Only two articles (Redmond and Dallas, 1990; Smith, 1990) mentioned visual outcome. There was no information to associate visual outcome with choice of general or local anesthesia. Most articles noted complications of surgery or anesthesia but were of poor quality.

### Recommendations for Care

The panel concurred that the choice of general or local anesthesia may affect visual outcome indirectly (i.e., through the effects of nausea, vomiting, or coughing after general anesthesia or sudden movement during local anesthesia) or directly. On balance, properly managed local anesthesia is simpler than general anesthesia, especially in patients with significant cardiac or pulmonary problems. Special monitoring techniques may be advisable in these patients. The panel concurred that the use of modern monitoring techniques is appropriate in cataract surgery, given the age of the patients and the high incidence of associated medical problems. Good monitoring might affect visual outcome indirectly if it prevents sustained hypertension, hypotension, or hypoxia.

The panel further believes that monitored anesthesia care by qualified anesthesia personnel is appropriate because the ophthalmologist is fully occupied in the surgical technique and therefore unable to deal with emergencies in a timely manner. Monitored anesthesia care includes physiologic monitoring with life-support systems available. The panel concurred that the administration of local anesthesia for cataract surgery is a skilled procedure and should be performed by an ophthalmologist or by another appropriately trained professional who has demonstrated competence in these techniques.

The panel agreed that there is a lack of studies in the literature addressing issues surrounding the administration of anesthesia for cataract surgery. The panel reached by consensus the following recommendations for care:

- Properly managed local anesthesia is preferred to general anesthesia and is appropriate unless precluded by extreme patient anxiety that does not respond to counseling or sedation, inability of the patient to cooperate with the surgical team, inability to provide satisfactory local anesthesia, known allergy to local anesthetic medications, and the presence of disorders that are best managed under general anesthesia (severe back pain, postural problems, etc.)
- Given the age of patients undergoing cataract surgery and the high incidence of associated medical problems, monitored anesthesia care provided by an anesthesiologist or anesthetist is justified and appropriate.
- Monitored anesthesia care should include the use of the following monitoring techniques: electrocardiogram, pulse oximetry, blood pressure, and respirations.
- The use of sedation drugs (reversible and with reduced side effects) is appropriate to minimize pain and discomfort while local anesthesia is being administered.
- Local anesthesia may be induced by the retrobulbar or peribulbar technique. Each has its own set of complications and advantages. The literature search did not identify evidence that one method was superior to others.
- The administration of peribulbar and retrobulbar anesthesia is a skilled procedure.
- It is in the best interest of the patient to have the safest local anesthesia possible administered by an individual fully trained in the procedure to be used.
- Because of the potential for extraocular complications (e.g., brain-stem anesthesia), peribulbar and retrobulbar anesthesia should be administered only to properly monitored patients with intravenous access established. There should be access to oxygen with assisted respirations via mask ventilation apparatus if necessary.

The panel also recommends that, in the patient's best interest, requirements for clinical competence to perform retrobulbar or peribulbar anesthesia be established to include training; supervision; knowledge of the appropriate anatomy, physiology, and pharmacology; and the ability to handle complications and consequences.

### Recommendations for Research

The panel recommends that research be undertaken on unresolved questions concerning the impact of anesthesia on the outcome of cataract surgery, including cost and cost-benefit analyses.

## Surgical Techniques and Complications

### Background

The dramatic revolution in cataract surgery over the last 15 years has been spearheaded by the adoption of microsurgical techniques. This includes the transition to the extracapsular cataract extraction (ECCE) procedure; the development of safe, effective IOLs; and the placement of the IOL behind the iris. The widespread acceptance of IOLs permitted satisfactory visual rehabilitation of patients with monocular cataracts who formerly would have been dependent on aphakic contact lenses. It is generally acknowledged that with these changes in technique, postoperative visual rehabilitation has improved to the point where surgical intervention is now appropriate at a much earlier stage of visual disability than had previously been possible.

Over the same period, modification of the surgical technique has continued on a variety of fronts. Most notable has been the introduction of phacoemulsification (PE) as a method of lens extraction. PE raises the expectation of enhanced safety and more rapid rehabilitation because of the reduced wound size needed. Alternative lens designs are also being explored to accommodate this decreased wound size and in an attempt to provide clear vision at both distance and near.

In this section, the type of surgical techniques (ECCE vs. PE) is considered in the context of effectiveness and complication rates. Lens design, secondary lens implantation, and other technical innovations are not within the scope of this guideline.

### Literature Review

#### Methods.

The purpose of the literature review was to identify and review the literature that contained information regarding surgical techniques and complications. The questions used to define potentially relevant articles are detailed in the Results section.

#### Results.

The systematic literature search identified 6,113 potentially relevant articles. Of these, 100 met the eligibility criteria established for this review. All of these articles underwent indepth methodologic and content reviews. The results of the literature review are as follows and are summarized in Evidence Tables K-1 to K-26 in Appendix K in the Guideline Report.

Overall, 57 studies examined visual acuity, 20 examined astigmatism, and 83 examined complications. On a study-specific basis, 4 studies examined only visual acuity, 31 examined only complications, 10 examined only astigmatism, 43 examined visual acuity and complications, none examined complications and astigmatism, and 7 examined visual acuity, complications, and astigmatism.

Among all the studies that examined visual acuity, the number of eyes studied ranged from 17 to 1,588. (The largest number of eyes studied by procedure was 756 for PE and 1,588 for ECCE.) Among all the studies that examined astigmatism, the number of eyes studied ranged from 50 to 503. (The largest number of eyes studied by procedure was 397 for PE and 503 for ECCE.) Among all the studies examining complications, the number of eyes studied ranged from 41 to 22,791. (The largest number of eyes studied by procedure was 2,704 for PE, 1,588 for ECCE, and 22,791 for a mixed group of PE and ECCE for which complications were reported for the entire group and not according to type of procedure used.)

The following is a summary of information on the principal outcomes and complications of cataract surgery. The data presented are exclusively from clinical series and observational studies. None of the studies that met the inclusion criteria involved random allocation of patients to various surgical procedures. Additionally, case mix (e.g., frequency of other significant eye disease in the study population), length of followup time, and definitions for specific complications varied tremendously by study. Therefore, great caution must be exercised both in examining specific rates as well as in pooling data across studies. Moreover, these methodologic limitations render any comparisons of outcomes between procedures (e.g., PE vs. ECCE) hazardous.

##### Question 1: Is there evidence that visual acuity after final refraction is better, no different, or worse when a cataract is extracted via standard ECCE vs. PE?

Of the articles that met the inclusion criteria, 57 examined visual acuity (Acheson, McHugh, and Falcon, 1988; Allen and Zhang, 1987; Azen, Hurt, Steel et al., 1983; Barrett, Beasley, Lorensetti et al., 1987; Barrett, Constable, and Steward, 1986; Brint, Ostrick, and Bryan, 1991; Cheng, 1987; Cinotti, Fiore, Maltzman et al., 1988; Cunliffe, Flanagan, George et al., 1991; Davison, 1984; Faulkner, 1987; Galand, Van Oye, Budo et al., 1985 ; Hara, 1986; Heslin and Guerriero, 1984; Komatsu, Kanagami, and Shimizu, 1989; Kooner, Cooksey, Perry et al., 1988; Kraff and Sanders, 1982; Kraff, Sanders, and Jampol, 1982; Kraff, Sanders, and Lieberman, 1983; Kraff, Sanders, Jampol et al., 1984 and 1985; Kratz, Mazzocco, and Davidson, 1979; Kratz, Mazzocco, Davidson et al., 1981a and 1981b; Levy and Pisacano, 1988; Liesegang, Bourne, and Ilstrup, 1990; Littlewood and Constable, 1985; Loh, Chew, Phua et al., 1985; Markoff, Levin, and Behar, 1985; Masket, 1989; McCaffrey and Lusby, 1986; Menapace, Skorpik, and Wedrich, 1990; Moschos, 1988; Naeser, Rask, and Hansen, 1986; Naylor and Sutton, 1989; Neumann and Cobb, 1989; Neumann, McCarty, Sanders et al., 1989; Noble, Hayward, and Huber, 1990; Pallin, 1987; Pedersen, 1990; Percival, 1987a and 1987b; Rich, Condon, and Percival, 1988; Ridgway, 1985; Shepherd, 1989a; Shimizu, 1988; Silvestri, Shepherd, and Johnston, 1989; Simcoe, 1981; Southwick and Olson, 1984; Stark, Maumenee, Datiles et al., 1983; Steinert, Brint, White et al., 1991; Story, 1988; Straatsma, Meyer, Bastek et al., 1983; Van Oye, Budo, Galand et al., 1986; Watts, 1986; Woodhams, Maddox, Hunkeler et al., 1984; Wright, Wilkinson, Balyeat et al., 1988). Visual acuity data were limited by a lack of documentation of preoperative data, including both visual acuity and documentation of ocular comorbid conditions that might limit postoperative acuity.

Thirty-three of the 57 provided data on the percent of eyes without preexisting eye disease that achieved visual acuity of 20/40 or better (Acheson, McHugh, and Falcon, 1988; Allen and Zhang, 1987; Barrett, Beasley, Lorensetti et al., 1987; Barrett, Constable, and Steward, 1986; Brint, Ostrick, and Bryan, 1991; Cheng, 1987; Cunliffe, Flanagan, George et al., 1991; Galand, Van Oye, Budo et al., 1985; Heslin and Guerriero, 1984; Komatsu, Kanagami, and Shimizu, 1989; Kratz, Mazzocco, and Davidson, 1979; Kratz, Mazzocco, Davidson et al., 1981b; Levy and Pisacano, 1988; Markoff, Levin, and Behar, 1985; Masket, 1989; McCaffrey and Lusby, 1986; Menapace, Skorpik, and Wedrich, 1990; Neumann, McCarty, Sanders et al., 1989; Pallin, 1987; Pedersen, 1990; Percival, 1987a and 1987b; Rich, Condon, and Percival, 1988; Shepherd, 1989a; Shimizu, 1988; Silvestri, Shepherd, and Johnston, 1989; Southwick and Olson, 1984; Stark, Maumenee, Datiles et al., 1983; Steinert, Brint, White et al., 1991; Story, 1988; Straatsma, Meyer, Bastek et al., 1983; Van Oye, Budo, Galand et al., 1986; Wright, Wilkinson, Balyeat et al., 1988). Of these 33 studies, 31 (94 percent) reported that greater than 90 percent of eyes achieved acuity of 20/40 or better (Allen and Zhang, 1987; Barrett, Beasley, Lorensetti et al., 1987; Barrett, Constable, and Steward, 1986; Brint, Ostrick, and Bryan, 1991; Cheng, 1987; Cunliffe, Flanagan, George et al., 1991; Galand, Van Oye, Budo et al., 1985; Heslin and Guerriero, 1984; Komatsu, Kanagami, and Shimizu, 1989; Kratz, Mazzocco, and Davidson, 1979; Kratz, Mazzocco, Davidson et al., 1981b; Levy and Pisacano, 1988; Masket, 1989; Markoff, Levin, and Behar, 1985; McCaffrey and Lusby, 1986; Menapace, Skorpik, and Wedrich, 1990; Neumann, McCarty, Sanders et al., 1989; Pallin, 1987; Pedersen, 1990; Percival, 1987a and 1987b; Rich, Condon, and Percival, 1988; Shepherd, 1989a; Shimizu, 1988; Southwick and Olson, 1984; Stark, Maumenee, Datiles et al., 1983; Steinert, Brint, White et al., 1991; Story, 1988; Straatsma, Meyer, Bastek et al., 1983; Van Oye, Budo, Galand et al., 1986; Wright, Wilkinson, Balyeat et al., 1988). The results of these 33 studies are summarized in Table 5-1.

Table 5-1. Visual Acuity Following Cataract Surgery

Percent of Eyes Reported To Be 20/40 or Better Postoperatively | Number (Percent) of Studies
>= 80 | 33 (100%)
>= 90 | 31 (94%)
>= 95 | 23 (70%)
>= 98 | 12 (36%)
100 | 6 (18%)

Source: Compiled from 57 articles, listed in the text, that addressed visual acuity.

These results emphasize the excellent visual results that are expected in patients without significant ocular comorbidity.

##### Question 2: Is there evidence that the time to final refraction is shorter, no different, or longer when a cataract is extracted via standard ECCE vs. PE?

One controlled study (Heslin and Guerriero, 1984) suggested that the time to final refraction was 8 days shorter for PE vs. ECCE. Studies available for the preparation of this document do not permit a conclusion to be drawn that differences in visual acuity at time of final refraction exist between PE and ECCE.

##### Question 3: Is there evidence that the incidence of occurrence of more than 2 diopters of astigmatism at the time of final refraction is greater, the same, or less when a cataract is extracted via standard ECCE vs. PE?

Twenty articles examined astigmatism (Axt, 1987; Brint, Ostrick, and Bryan, 1991; Brown and Sparrow, 1988; Cory, 1989; Davison, 1984; Dixon, 1989; Gills and Sanders, 1991; Heslin and Guerriero, 1984; Jampel, Thompson, Baker et al., 1987; Kraff and Sanders, 1982; Maltzman, Cinotti, Horan et al., 1983; Masket, 1985 and 1990; Moschos, 1988; Naeser, Rask, and Hansen, 1986; Neumann, McCarty, Sanders et al., 1989; Pallin, 1987; Parker and Clorfeine, 1989; Shepherd, 1989a; Woodhams, Maddox, Hunkeler et al., 1984). Studies on residual postoperative astigmatism were limited methodologically by inconsistent reporting of preoperative astigmatism and the reporting of summary data for entire surgical populations, thereby not permitting the actual comparison of preoperative and postoperative astigmatism for individual patients. Additionally, there was extreme variation in the duration of time after surgery for which levels of astigmatism were reported. A commonly reported target for this outcome is a degree of astigmatism of less than or equal to 2 diopters postoperatively. Of 12 studies reporting on this target (Axt, 1987; Brint, Ostrick, and Bryan, 1991; Brown and Sparrow, 1988; Cory, 1989; Davison, 1984; Jampel, Thompson, Baker et al., 1987; Masket, 1985 and 1990; Moschos, 1988; Parker and Clorfeine, 1989; Shepherd, 1989b; Woodhams, Maddox, Hunkeler et al., 1984), 6, or 50 percent (Axt, 1987; Brown and Sparrow, 1988; Masket, 1985 and 1990; Parker and Clorfeine, 1989; Shepherd, 1989a) reported that greater than 90 percent of eyes had less than 2 diopters of astigmatism. The remaining six studies (Brint, Ostrick, and Bryan, 1991; Cory, 1989; Davison, 1984; Jampel, Thompson, Baker et al., 1987; Moschos, 1988; Woodhams, Maddox, Hunkeler et al., 1984) reported that at least 70 percent of the eyes had less than 2 diopters of astigmatism. Three of the four controlled studies (Heslin and Guerriero, 1984; Kraff and Sanders, 1982; Neumann, McCarty, Sanders et al., 1989) suggest that the change in astigmatism is less for PE than for ECCE. In the remaining study (Pallin, 1987), the change in astigmatism was not significantly different. These findings are consistent with the hypothesis that the absolute level of postoperative astigmatism decreases with the size of the surgical wound, since smaller incisions are typically used with PE vs. ECCE. However, these studies do not address whether the measured differences are of clinical significance to patients. Thus, available studies do not permit a conclusion to be drawn that clinically significant differences in astigmatism exist between PE and ECCE.

##### Question 4: Is there evidence that the incidence of certain ophthalmologic complications is greater, the same, or less when a cataract is extracted via standard ECCE vs. PE?

Eighty-three articles addressed rates of other complications (Acheson, McHugh, and Falcon, 1988 ; Allen and Zhang, 1987; Arnott and Condon, 1985; Arnott, Grindle, and Krolman, 1988; Azen, Hurt, Steel et al., 1983; Barrett, Beasley, Lorensetti et al., 1987; Barrett, Constable, and Steward, 1986; Born and Ryan, 1990; Bukelman, Hoffman, and Oliver, 1987; Cheng, 1987; Cinotti, Fiore, Maltzman et al., 1988; Coonan, Fung, Webster et al., 1985; Cunliffe, Flanagan, George et al., 1991; David, Tessler, Yagev et al., 1990; Davison, 1984 and 1988; Frezzotti and Caporossi, 1990; Galand, Van Oye, Budo et al., 1985; Hansen, Naeser, and Rask, 1987; Harris and Kogan, 1981; Heslin and Guerriero, 1984; Kattan, Flynn, Pflugfelder et al., 1991; Komatsu, Kanagami, and Shimizu, 1989; Kooner, Cooksey, Perry et al., 1988; Kooner, Dulaney, and Zimmerman, 1988; Kraff and Sanders, 1982 and 1990; Kraff, Sanders, and Jampol, 1982; Kraff, Sanders, Jampol et al., 1984 and 1985; Kraff, Sanders, and Lieberman, 1983; Kratz, Mazzocco, and Davidson, 1979; Kratz, Mazzocco, Davidson et al., 1981a and 1981b; Levy and Pisacano, 1988; Liesegang, Bourne, and Ilstrup, 1985 and 1990; Littlewood and Constable, 1985; Loh, Chew, Phua et al., 1985; Markoff, Levin, and Behar, 1985; Maynor, 1983; McCaffrey and Lusby, 1986; Menapace, Skorpik, and Wedrich, 1990; Milauskas, 1987 and 1990; Moisseiev, Bartov, Schochat et al., 1989; Moschos, 1988; Naeser, Nielsen, and Hansen, 1990; Naeser, Rask, and Hansen, 1986a and 1986b; Naylor and Sutton, 1989; Naylor, Sutton, Morrell et al., 1989; Neumann and Cobb, 1989; Neumann, McCarty, Sanders et al., 1989; Nishi, 1986; Noble, Hayward, and Huber, 1990; O'Donnell and Santos, 1985and 1990; Pedersen, 1990; Percival, 1987a and 1987b; Raines, Corridan, and O'Neill, 1989; Rich, Condon, and Percival, 1988; Ridgway, 1985; Sellman and Lindstrom, 1988; Severin and Severin, 1988b; Sheets, 1987; Silvestri, Shepherd, and Johnston, 1989; Simcoe, 1981; Simel, 1982; Smith, Stark, Maumenee et al., 1987; Southwick and Olson, 1984; Stark, Maumenee, Datiles et al., 1983; Steinert, Brint, White et al., 1991; Sterling and Wood, 1986; Story, 1988; Straatsma, Meyer, Bastek et al., 1983; Stur, Grabner, and Dorda, 1984; Taylor, Sachs, and Stern, 1984; Van Oye, Budo, Galand et al., 1986; Watts, 1986; Woodhams, Maddox, Hunkeler et al., 1984; Wright, Wilkinson, Balyeat et al., 1988). Although there was considerable variation among all studies in the rates of five major clinical complications, the rates obtained from the studies with the largest sample sizes are as shown in Table 5-2.

Table 5-2. Complications of Cataract Surgery

Complication | Rate (Percent)
Bullous keratopathy | < 0.3
Malposition or dislocation of the intraocular lens | < 1.0
Endophthalmitis (intraocular infection) | < 0.3
Retinal detachment | < 1.0
Clinically significant cystoid macular edema (postoperative swelling of the central retina) | < 3.0

Source: Compiled from 83 articles, listed in the text, that addressed rates of complications.

Available data in the published literature do not permit reasonable conclusions to be drawn that differences in the rates of these major complications exist between PE and ECCE. This is also true for other complications, including anterior chamber hemorrhage, hypopyon, chronic uveitis, iris trauma, increased open-angle intraocular pressure (IOP), increased closed-angle IOP, PSC opacification, zonular or posterior capsule rupture, loss of nuclear fragment into vitreous, vitreous hemorrhage, choroidal hemorrhage, retinal ischemia or infarction, angiographically proven cystoid macular edema, optic neuropathy, and ptosis.

##### Question 5: Does the literature provide data concerning the impact of cataract surgery on overall function of the patient?

No articles that met the inclusion criteria examined changes in visual function, as measured by everyday activities. Of these, one article (Masket, 1989) examined changes in contrast sensitivity and glare disability, which are outcomes related to visual function. Nine other articles (Applegate, Miller, Elam et al., 1987; Bernth-Petersen, 1981; Donderi and Murphy, 1983; Elam, Graney, Applegate et al., 1988 ; Hilbourne, 1975; Hill, 1982; Immonen, Tuominen, and Raivo, 1988; OCTET, 1987; O'Malley, Newmark, Rothman et al., 1989) that examined visual function or health status were excluded; these articles did not fulfill the selection criteria because the type of surgery or IOL was not specified. Most of these studies demonstrated that cataract surgery results in significant improvements in visual function and health status, such as everyday activities and emotional health, in the first year after surgery.

For a full description of the methodology and findings of the literature review, see Appendix K in the Guideline Report.

The scope of the review of the literature in this guideline addresses a comparison of the two forms of extracapsular surgery, ECCE and PE. The review, however, did not deal with the details of surgical techniques, adjunctive agents used in facilitating the procedures, use of instruments for cataract removal, selection of types and styles of IOLs, techniques of IOL implantation, and the consequences of applying such materials and methods.

### Benefits and Harms of Cataract Surgery

Although no data precisely define the risks and benefits of cataract surgery, some estimates can be made based on literature reports of outcome and complications.

#### Benefits of Cataract Surgery: Positive Outcomes.

A positive outcome is the degree to which the presurgical functional impairment is relieved by the surgery, as defined by the types of benefits perceived by the patient, members of the patient's family, or the ophthalmologist who performs the surgery. Cataract surgery is a highly successful procedure. A visual result in the 20/40 to 20/15 range and an increase in well-being and quality of life can be anticipated in the vast majority of eyes without comorbidity. Generally, patients can expect an increase in well-being and quality of life 90 percent of the time. The following is a list of the types of benefits that could accrue as part of a positive outcome following cataract surgery.

- Increased ability to read or do close work.
- Increased ability to perform minimal everyday activities.
- Increased opportunity to continue or resume function or occupation (working, playing, driving) due to improvement in vision.
- Restoration of functional ability to precataract level.
- Increased mobility.
- Increased independence.
- Better uncorrected vision.
- Improved color vision.
- Reduced glare disability.
- Improved depth perception.
- Increased ability to retain a quiet eye with no treatment-induced disorders.
- Patient satisfaction with the results of surgery.
- Improved sense of mental well-being.
- Improved self-esteem.
- Relief from fear of going blind.
- Increased ability to avoid injury.
- Increased interpersonal contact.
- Increased opportunity for medical observation of the internal eye for incipient or impending diseases.

#### Harms of Cataract Surgery: Negative Outcomes.

Harms that may occur as a result of the expected surgery may be defined as negative outcomes. These include failure to achieve the expected positive outcomes or failure to relieve or improve the preoperative functional impairment as perceived by the patient, the patient's family, or the ophthalmologist who performed the surgery. In addition, negative outcome refers to the development of complications that either impair the patient's visual function or consume resources (Table 5-3). It should be noted that these complication rates are based on data obtained from the literature review and the consensus of the panel. Therefore, they should be considered only estimates.

Table 5-3. Estimated Rate of Negative Outcomes of Cataract Surgery

>= 1:100 | < 1:100 | < 1:1,000 | < 1:10,000 | < 1:100,000
Glaucoma | Dislocated lens | Depression | Loss of eye | Death
Ptosis | Dilated pupils | Loss of vision | Chronic pain | Suicide
Intraocular hemorrhage | Endophthalmitis | Double vision | Psychosis
Problems with glare | Increased need for ocular medication | | Expulsive hemorrhage
Cystoid macular edema | Retinal detachment | | Systemic disease as a result of surgery
Adverse effects from drugs used in the treatment Increased ultraviolet exposure Need for further surgery | Bullous keratopathy

Note: Except for glaucoma, ptosis, increased ultraviolet exposure, and depression, the rate increases when there are comorbid conditions. Source: Compiled from reviewed literature and panel consensus.

The success rate of cataract surgery is reduced in the presence of comorbid ocular conditions. Again, data are lacking for precise estimates of this effect, but conditions such as corneal disease leading to loss of corneal clarity, glaucoma, and retinal disorders such as retinal detachment disease, macular degeneration, and diabetic retinopathy all contribute to loss of vision and, therefore, loss of the effect of the cataract surgery. The effects may be immediate (that is, proximate to the time of the surgical effect) or may become manifest a considerable period after the surgery is complete.

### Conclusions From the Literature Review

The rate of visual improvement, degree of astigmatism, and incidence of other complications in studies with large sample sizes indicate that both ECCE and PE are safe and effective procedures. The panel felt that it was logical that small-incision (i.e., less than or equal to 4 mm) cataract surgery would cause less astigmatism than traditional cataract surgery, which is performed with a larger incision (10 mm). The panel also found some published evidence (Neumann, McCarty, Sanders et al., 1989) that is consistent with this hypothesis. However, the panel felt there were inadequate published data available as of the date of literature review to determine whether there were clinically significant differences in the amount of astigmatism that occurs in association with PE (particularly small-incision PE) vs. standard ECCE.

### Conclusions of the Panel

Based on the evidence in the literature, the panel reached the following conclusions:

- Modern cataract surgery is safe and effective in restoring vision in patients with cataracts. Complication rates of modern cataract surgery are low. When complications do occur, however, they are often serious and vision threatening. It is of particular importance that the ophthalmologist who performed the surgery or is responsible for patient care during the postoperative period be prepared to diagnose and manage these conditions promptly and effectively. Effective treatment may require extensive additional complicated surgical procedures (e.g., glaucoma surgery, retinal detachment surgery, therapeutic vitrectomy, penetrating keratoplasty, or anterior segment revision). Prompt diagnosis and management of these conditions is a basic tenet of appropriate medical care.
- In the absence of comorbid conditions, a postoperative corrected visual acuity in the 20/40 to 20/15 range is a reasonable expectation for the vast majority of patients with functional impairment due to cataract. PE and ECCE surgery appear to be equally effective in restoring vision.
- The motivation for using PE in cataract surgery is enhanced safety coupled with a more rapid rehabilitation following the procedure. The rationale is that the smaller wound promotes less likelihood of wound dehiscence, more rapid healing, and reduced postoperative astigmatism. In addition, this may be advantageous in some eyes with comorbid conditions. Although these concepts are intuitively appealing, it is not possible to determine from the published literature, in a definitive manner, whether the use of the PE technique leads to a more rapid functional rehabilitation of the patient; whether the use of PE leads to less induced postoperative astigmatism; or whether specific or overall complication rates associated with PE are better, worse, or unchanged compared with the rates associated with the standard extracapsular procedure.
- Studies in the published literature demonstrate that cataract surgery results in significant improvement in visual function and overall functional status in the first postoperative year. It is not possible, however, to determine whether the use of PE over the standard extracapsular procedure enhances the outcome when measured by reduction or elimination of functional impairment due to cataract.

### Recommendations for Care

The questions raised in this portion of the literature review are central to the debate concerning technical innovations in surgery, namely the indications, contradictions, complaints, benefits, and risks of one technique as opposed to the other.

In the absence of specific guidance from the published scientific literature, the panel recommends that ophthalmologists use their best judgment in selecting the surgical techniques for individual patients with cataract. This decision regarding the appropriate technique should be made by the ophthalmologist who is to perform the surgery according to his or her training and experience and after discussion with and explanation to the patient.

It is the responsibility of the ophthalmologist who is to perform the surgery to do the following:

- Ensure that the patient has had a general medical history and physical examination as appropriate to the planned surgery and the type of anesthesia.
- Ensure that the appropriate keratometry and A-scan measurements have been performed, if an IOL is to be implanted.
- Select the appropriate IOL power after discussion with the patient, if an IOL is to be implanted.
- Review the results of presurgical and diagnostic evaluation of the patient and discuss the findings with the patient or, in appropriate cases, with another responsible adult acting for the patient.

In considering all possible benefits and harms, comorbid conditions must be taken into account. The degree to which they are treatable or being treated, or that surgery is modified to account for them, will influence the outcome. Overall, in the presence of these conditions, the success rate of the surgery is reduced from the overall high level of expected outcome in the eye without comorbid conditions. Visual loss with these comorbid conditions may occur even without surgery.

### Recommendations for Research

The panel recognizes that the literature lags behind current practice in evaluating changes in clinical practice such as surgical technique. As a result, data on effectiveness and complications reported in the literature may not apply to current clinical practice.

The panel recommends that research be undertaken to develop innovative approaches for evaluating surgical outcomes so that timely data can be derived.

## Second Eye Surgery

Indications for second eye surgery are the same as for first eye surgery.

### Background

When an individual who has already had cataract surgery in one eye develops a vision-impairing cataract in the second eye, the patient and the ophthalmologist are confronted with the same issues regarding the decision for surgery that were present during the development of the cataract in the first eye. This section of the guideline addresses the indications for cataract surgery in the second eye and the timing of the surgical intervention.

### Literature Review

#### Methods.

The literature review process is described fully in Appendix L in the Guideline Report.

#### Results.

The results of the literature review are as follows and are summarized in Evidence Table L-1 in Appendix L in the Guideline Report.

##### Question 1: Is there evidence of the indications for surgery on the second eye?

No articles were available to directly address this question. One paper (Bernth-Petersen, 1982) suggested that the need for binocularity is an indication for bilateral surgery. However, the study was performed on aphakics, no patients were pseudophakic, and followup was lost on 7 percent of the patients. There were no data on comparability of the group or reasons for bilateral vs. unilateral surgery. The second study (Maruszczak, Jensen, and Goldschmidt, 1979), performed on 100 patients below the age of 60 who were made surgically aphakic, investigated the correlation of occupational and visual needs with surgery in one or both eyes. The authors concluded that operation for unilateral cataract was inadvisable as it leads to intolerable anisometropia. Again, the study was performed only on aphakic eyes. Thirty percent of the data were missing because of loss of comparability of the group or the reasons for bilateral vs. unilateral surgery. This conclusion seems intuitively reasonable, but the fact that the study was carried out on aphakics means that this may not be directly applicable to pseudophakic patients unless there is marked refractive disparity between the two eyes.

##### Question 2: Is there evidence to support or refute an association between surgery on the second eye and the overall outcome? (Consider reduction of functional impairment in particular.)

No papers were found providing evidence to answer this question. However, Bernth-Petersen (1985), a review paper, analyzed a series of 12 studies that dealt with the subject of outcome. This included review of Bernth-Petersen (1982). As a result of this review, the author felt that patients with both eyes operated on were likely to be more comfortable than patients having surgery on one eye. This is particularly true of patients who were aphakic. The author also found that the monocular pseudophakes and contact lens-corrected patients appear to be more satisfied than monocular aphakic patients or aphakic patients corrected with spectacles.

##### Question 3: Is there information on cost and/or cost-benefit issues?

No papers were found that directly addressed this issue.

Cost-benefit issues were only touched on in some of the papers. Nevertheless, as with the suggestions for indications and outcomes, there were a few conclusions. Restoration of binocularity, especially in working individuals, was helpful in restoring a productive person to his or her optimum status, thereby indirectly stimulating the economy and eliminating disability benefits. Also, in certain circumstances, performing surgery on both eyes in the same operating session was "economical." Once again, these data were not presented with much statistical support.

In addition, five papers (Benerza and Chirambo, 1978; Engelbrecht and Stulting, 1984; Fenton and Gardner, 1982; Henderson, 1977; Maruszczak, Jensen, Goldschmidt et al., 1979) discuss bilateral cataract surgery at the same sitting. All patients were aphakic, so the relevance to the pseudophakic patient and modern cataract surgery is questionable. These papers suffered from a variety of methodologic defects, as outlined in the evidence table. However, they do indicate the low rate of complications using this particular approach. Clayman, Jaffe, Light et al. (1977) discusses the results of cataract surgery in 730 patients, 44 of whom had bilateral implants. The authors advise a conservative approach toward surgery in the second eye in order to evaluate the success of the procedure in the first eye. This paper was written 14 years ago, when implant surgery was still being perfected, so its application to modern surgery is also questionable.

### Conclusions From the Literature Review

None of the papers identified in this literature search contained information relevant to the questions posed. No precise indications for cataract surgery on the second eye were identified. The majority of these studies were on aphakic patients and, thus, were of doubtful relevance to the modern pseudophakic eye in patients. Several studies addressed outcome following bilateral surgery. Cost-benefit issues to the patient and the community were not addressed. All these papers contained a variety of methodologic defects, which considerably lessened the impact of the conclusions drawn by the authors; these are summarized in the comments of the evidence table.

The search of the literature did not reveal answers to the questions specified by the panel regarding surgery on the second eye.

### Conclusions of the Panel

Although the studies concerning indications and outcomes for surgery on the second eye had significant limitations, they nevertheless provided some strong suggestions about the need for such surgery. The disabilities caused by a visual deficit in the second eye are significant (e.g., loss of binocularity and stereopsis). Since measures of visual function such as acuity, stereopsis, and visual field are all enhanced by binocular vision, the panel felt that these facts strongly support the potential benefit of surgery in the second eye. The existence of anisometropia and often aniseikonia due to disparate refractive errors, as well as the unequal visual acuity due to the presence of the cataract in the second eye, are factors that bring both patient and surgeon to the decision to operate on the second eye, even after successful visual rehabilitation of the first eye.

Costs and benefits were touched on only in some of the papers. Nevertheless, as with the suggestions for indications and outcomes, there were a few conclusions. Restoration of binocularity, especially in working individuals, was helpful in restoring productive people to their optimum status, thereby indirectly stimulating the economy and eliminating disability benefits. Also, in certain circumstances, performing surgery on both eyes in the same operating session was considered to be economically justified, although this runs the very real risk of catastrophe if there is an unrecognized problem with unsterile instruments or materials used in both eyes. Once again, these data have limited statistical support.

### Recommendations for Care

In light of the lack of scientific documentation, the panel offers the following conclusions by consensus after considering the policy statement from the American Academy of Ophthalmology (1991) regarding surgery on the second eye.

When a patient with functional impairment due to bilateral cataracts has undergone surgery in one eye, surgery in the second eye is justified and appropriate when the subjective, objective, and educational criteria (outlined in the section on indications for surgery) are met. The patient and the ophthalmologist should then proceed to evaluate the need for cataract surgery in the second eye, as outlined in the section on surgical techniques and complications. As part of this evaluation, the patient should be educated about the possibility of a subsequent complication in the first eye. In the event a patient initially decides to defer surgery on the second eye, the opportunity for surgery in the future should not be denied.

There are no scientific data to indicate the optimal time interval for surgery on the second eye. The panel agrees that judgment regarding this time interval should be based on the following factors. In no case should surgery be done on both eyes at the same surgical procedure.

- The patient is able to provide informed consent for surgery on the second eye after evaluating the visual results and postoperative course of surgery on the first eye.
- Adequate time has passed to detect and treat the most immediate vision-threatening complications of cataract surgery.
- Vision in the operated eye has recovered sufficiently that the patient is not at risk of injury due to functional impairment during second eye cataract surgery and the immediate postoperative period.
- In the event that vision has not recovered or is not recoverable, there is time to arrange for adequate assistance so the patient is not at risk of injury due to functional impairment following second eye cataract surgery.

The following factors may influence the patient's and surgeon's judgment regarding the timing of surgery on the second eye:

- The distance from home of the nearest available facility for surgery and appropriate postoperative care.
- The patient has a need (e.g., occupational) for good binocular vision within a limited timeframe after the first eye surgery.
- The patient is symptomatic due to postoperative anisometropia.

Early spectacle correction or decrease in the duration of the postoperative course alone, however, is not adequate justification for performing surgery on the second eye before the patient and the ophthalmologist have had sufficient opportunity to evaluate the results from the surgery on the first eye.

An exception to these indications is the special case where the opposite eye has no useful vision. In this case, the decision for surgery is determined by the degree of vision reduction at the time the patient enters into the evaluation process. In some cases, surgery may be delayed because of the greater potential for total blindness in the event of a serious complication of surgery. It is then the obligation of the ophthalmologist to inform and educate the patient about the potential risk of total blindness. Although the decreased visual acuity and level of disability may fall well within the guidelines for cataract surgery, the worse the vision is in the fellow eye, the greater the need is for caution in considering cataract surgery in a patient's only seeing eye.

### Recommendations for Research

It is clear from a review of the literature that the questions surrounding the decision to operate on the second eye have received insufficient attention in the scientific literature. The panel recommends that research be undertaken to investigate the benefits of surgery on the second eye as opposed to the benefits of surgery on one eye only, and the optimum time for that surgery to be performed when the patient has functional impairment from binocular cataracts. The cost-benefit issues related to this topic are also important and should be analyzed.