# Guideline: Setting and Providers of Care

Cataract surgery should be performed where patients can receive quality care in a safe environment, close to home if at all possible or close to the best social support system of family and friends. The ophthalmologist who performs the surgery has the responsibility and ethical obligation to the patient for care during the postoperative period.

## Background

During the past 15 years, improvements in cataract surgical techniques have led to major changes in the surgical setting and the approach to care before and after surgery. In the past, cataract surgery was an inpatient procedure requiring hospitalization for up to 7 days. Today, most cataract surgery is performed as an outpatient procedure in an ambulatory surgery center or a hospital-based outpatient surgical center. The care rendered in these two settings may not be assessed as rigorously as the care rendered in the hospital setting. In the hospital setting, there is formal institutional surveillance of peer review and quality assurance, a joint hospital accreditation process, plus the informal surveillance of other physicians and the many different types of staff personnel that may be present.

Traditionally, the ophthalmologist who performed cataract surgery provided the preoperative and postoperative care. Changes in Medicare coverage and reimbursement have encouraged a number of ophthalmologists to work with independent, nonsurgically trained providers to provide perioperative care. Efforts by a few ophthalmologists to provide less direct care and still achieve successful results have in some instances resulted in situations where the ophthalmologist who performed the surgery relegated postoperative care to nonophthalmologist health care providers.

On April 1, 1987, Medicare coverage was expanded to permit reimbursement to optometrists as physicians (as defined in the Social Security Act governing Medicare), within the legal authorizations of the States in which they practice. The expansion of coverage did not delineate the division of responsibility between an ophthalmologist and an optometrist working independently or between an ophthalmologist and an optometrist working in the same setting providing shared care. It is not known whether changes in the setting of surgery and in the delegation of perioperative care to those working independently of the ophthalmologist who performed, or is to perform, the surgery are medically safe and appropriate, and whether these changes have altered the outcome, cost, and quality of providing cataract surgical care. Is it safe and appropriate for a surgeon to delegate all or part of the postoperative care to an independent provider who was not involved in the surgery and may not have the education, competence, or knowledge to make the requisite clinical judgments?

Nothing is known regarding the quality and long-term outcome of cataract surgery under these circumstances, particularly as they relate to the diagnosis and management of complications, nor is there information regarding differences in cost. Is there any difference in the cost of providing surgery in one setting over the other? Is there any difference in cost when the postoperative care is provided by an ophthalmologist as opposed to an optometrist? In a report issued in April 1989, the Office of the Inspector General expressed concern over situations in which abusive referral arrangements resulted in Medicare overpayments and kickbacks (Department of Health and Human Services, 1989).

Presently, there are no data in the published literature regarding the most appropriate division of responsibility for postoperative care following cataract surgery. However, there is a generally accepted belief that the operating ophthalmologist, being the most knowledgeable about what took place at surgery, is in the best position to diagnose and deal with surgically related complications and has the ultimate responsibility for a successful outcome.

## Literature Review

### Methods

The purpose of the literature review was to determine whether there is evidence in the published literature to support or refute an association between the outcome of cataract surgery and the overall setting of care. (See Appendix C in the Guideline Report for a full discussion of the literature review process.)

### Results

Each of 18 articles was evaluated with reference to the search questions. The results of the literature review are given here and summarized in Evidence Table C-1 in Appendix C of the Guideline Report.

#### Question 1: Is there evidence to support or refute an association between outcome following cataract surgery and the identity and/or qualifications of the individual performing the initial workup (optometrist, ophthalmologist, generalist/primary care physician)?

No articles were found to address this question.

Revicki, Brown and Adler (1990) identified a pattern of optometrists referring cataract patients to ophthalmologisst at ambulatory eye centers for complete eye examinations and surgery if needed. The article did not analyze the association between this referral pattern and outcome of surgery.

#### Question 2: Is there evidence to support or refute an association between outcome following cataract surgery and the length of association between the patient and the physician postoperatively?

#### Question 3: Is there evidence to support or refute an association between outcome following cataract surgery and the location of the surgery (ambulatory surgical center vs. hospital)?

No articles were found to address these questions.

#### Question 4: Is there evidence to support or refute an association between outcome following cataract surgery and the volume of cataract surgery performed by the provider?

Six studies (Farrell and Deichman, 1981; Kersten and Kolder, 1982; Neuhaus and Straatsma, 1983; Schanzer and Wilhelmus, 1985; Straatsma, Meyer, Bastek et al., 1983; Wong and Kline, 1982) of residents in training in the United States revealed that supervised resident surgeons in training had a high surgical success rate, and their complication rate during their first 100 or fewer cases did not differ significantly from that of more experienced surgeons. One study (Sutton, 1980) of surgeons in training in England reported a higher incidence of late complications in patients undergoing cataract surgery with intraocular implantation. The linkage of the higher complication rate to the surgeon's experience is uncertain, since this late complication of corneal decompensation may well have been due to poor intraocular lens (IOL) design (iris loop lenses).

#### Question 5: Is there evidence to support or refute an association between outcome following cataract surgery and the qualifications and/or identity of the individual providing postoperative care (medical doctor vs. optometrist, surgeon vs. delegated medical doctor, high-volume vs. low-volume provider)?

No articles were found to address this question.

Revicki, Brown, and Adler (1990) described complication rates when optometrists followed the patients during one or more visits in the 3 months after surgery. The study concluded that patients receiving postoperative care delivered by optometrists had visual outcome and complication rates that were comparable to those reported in the medical literature where all care is delivered by ophthalmologists.

The study was done in response to a Congressional Office of Technology Assessment report on "comanaged care" that implied that optometrists, because of differences in training compared with ophthalmologists, might not deliver acceptable postoperative care following cataract surgery (Kemp and Boardman, 1988).

Problems with the study relate to both internal validity -- the extent to which the study provides valid information about the sample studied -- and external validity -- the extent to which the results are generalizable to other settings. Internal validity problems relate to sample selection, data collection, unstandardized interventions, choice of outcome measures, data analysis, and the inferences of the authors. Problems with external validity include selection bias, study intervention, lack of proper comparison groups, and the inferences drawn by the authors. Thus, it is not possible, on the basis of this publication, to support or refute the hypothesis that postoperative care delivered by optometrists and ophthalmic surgeons is comparable with that administered by the ophthalmic surgeon alone. (For full review, see Appendix A in the Guideline Report.)

#### Question 6: Is there evidence to support or refute an association between outcome after cataract surgery and the distance of the patient's home from the surgical and/or office site?

#### Question 7: Is there evidence to support or refute an association between outcome after cataract surgery and the availability of emergency care?

#### Question 8: Is there evidence to support or refute an association between outcome after cataract surgery and the context and identity of the person(s) providing postoperative home care (self, family, visiting nurse, nursing home, other)?

No articles were found to address these questions.

#### Question 9: Is there information on an association between outcome after cataract surgery and cost and/or cost-benefit issues?

No article was found addressing the cost-benefit issue of outpatient surgery in an ambulatory surgery center vs. a hospital-based outpatient setting. Four articles described how outpatient surgery is less costly than inpatient surgery (Bloom and Krueger, 1988; Davies, Limacher, and Powell, 1987; Stephenson, 1985; Williamson, 1975). However, this issue is no longer current.

No article was found to suggest that the volume of cases referred by the surgeon was a factor in determining cost effectiveness.

No study was found to document that having optometrists perform part or all of the postoperative care was more cost efficient than having ophthalmologists perform the care.

No article was found to link availability of emergency care with cost.

### Discussion

In the classification of these papers, only three broad categories were identified. One set focused on the clinical outcomes and complications associated with the provision of cataract surgical care by ophthalmologic resident physicians in training, often in comparison with faculty surgeons. There were seven studies in this category. The second category included five studies that focused on the measurement of the impact of the ambulatory provision of cataract surgical care in relation to inpatient surgery. The remainder dealt with various aspects of the organization and provision of ophthalmologic care (such as cost, quality, patient satisfaction, and the provision of care by optometrists and nurses to cataract patients) on the outcomes and complications of cataract surgery.

There is great variability among the studies reviewed. There appears to be a lack of consensus as to the most salient clinical or policy questions. Within those small clusters of projects that seem to study the same general issue, there is great variability in how the problem is formulated and in the way the principal variables are measured and results interpreted.

The lack of a "gold standard" for the measurement of the most important clinical outcomes seems to hamper these studies as a whole.

Few of the studies accounted for baseline differences among subjects (case mix) that might influence the clinical outcomes of greatest interest.

### Summary

The set of papers reviewed here are, in general, methodologically weak and rely on nonexperimental methods with unspecified and unstandardized measures of either the independent or dependent variables of greatest importance. Most of the design inadequacies of these studies are correctable within feasible bounds of cost and convenience for those who would seek to answer these questions through further research. Moreover, the answers to these questions will make available information of considerable value to emerging public policy in the field of health and medical care.

### Conclusions From the Literature Review

It is not possible to draw firm conclusions from the available scientific literature on these subjects regarding the influence of the type of provider, type of setting, or other features of the setting within which cataract surgical care is provided and the most common clinical outcomes (e.g., visual acuity and surgical complications). There seem to be strong suggestions in the existing literature that surgery performed (under supervision) for cataracts can be satisfactorily provided by residents with 2 or 3 years of postgraduate training with little difference in the critical indicators of clinical outcomes.

## Conclusions of the Panel

### Site of Surgery

In the absence of data in the published literature, the panel reached the following conclusions by consensus.

Surgery should be performed where the patient can receive quality care in a safe environment, close to home if at all possible or close to the best social support system of family and friends. An outpatient setting can be in a hospital or in an independent surgery center. The selection of the site is the responsibility of the ophthalmologist who performs the surgery because the ophthalmologist is ultimately responsible for the care of the patient and is best qualified to judge the adequacy and safety of an operative setting.

The selection of the site of surgery should not be influenced by any financial relations between the operating ophthalmologist and the surgical facility or with the owners of the operating room. The selection of the site of surgery should not be influenced by the source of the patient referral.

The proximity of the setting for preoperative and postoperative care to the surgical site is important. In most cases, it is preferable that the perioperative care and surgery be performed in the same community. Proximity to the surgeon facilitates good postoperative care and is especially important when complications arise.

Sometimes a patient may choose to have surgery at a site far from home so that the postoperative course is with family or friends who can provide social, psychological, and practical support through the early postoperative period.

When the patient with cataract seeks surgery by an ophthalmologist located far from home, the provision of postoperative care by the ophthalmologist who performs the surgery becomes impractical; in that instance, the ophthalmologist should educate the patient about the importance of the continuum of the care process involved in cataract surgery. This includes the preoperative phase, the surgical procedure, and the period of postoperative care. If the patient still desires to have the surgery far from home, the ophthalmologist who is to perform the surgery should make formal and explicit arrangements before surgery for the provision of appropriate postoperative care that includes the capacity for dealing with complications and emergencies in a timely manner. The arrangements should include advice regarding temporary accommodations in the area where surgery is to be performed.

If anyone other than the operating ophthalmologist is to provide all or most of the postoperative care, then the operating ophthalmologist has an obligation to inform the patient before surgery of the arrangements and of the relative qualifications of the postoperative caregiver. The ophthalmologist assuming responsibility for the patient's postoperative care should be fully conversant with the surgical procedure and any unusual events or complications that occurred at the time of surgery and be fully capable of providing appropriate surgical intervention if required.

### Providers of Care

The literature review failed to reveal useful information on important issues regarding providers of care. The panel reached the following conclusions by consensus.

From the patient's perspective, the operating ophthalmologist has a unique insight into and understanding of the patient's postoperative conditions, since he or she performed the surgery. Individual differences in cataract and individual differences in patient responses to surgery may lead to variations in the immediate postoperative outcome even in an uncomplicated operation.

The panel unanimously agreed that since the ophthalmologist who performs the surgery does so after discussing his or her assessment of the risks and benefits with the patient and after obtaining informed consent, and since that ophthalmologist has the most intimate knowledge of what took place at the time of surgery, he or she has the responsibility and ethical obligation to the patient for care during the postoperative period. The responsibility and obligation arise on the basis of the covenant that exists between the surgeon and the patient (see Ethics: The Relationship Between Caregiver and Patient, in the Overview).

From the patient's perspective, the period of postoperative care spans the interval from the conclusion of surgery until the goal of surgery is achieved by the attainment of stable improved vision. In the absence of complications, this usually occurs by 3 months after the surgery and coincides with the prescription of a final refractive correction. It also marks the point at which wound healing has sufficiently advanced so that the integrity of the eyeball has been reestablished and most short-term intraoperative and postoperative complications have been diagnosed and treated.

If ophthalmic medical and surgical postoperative complications develop, it is the obligation of the ophthalmologist who performed the surgery to provide treatment or, with the consent of the patient, to refer him or her to another ophthalmologist, depending on the nature of the problem. This treatment may need to extend beyond the postoperative period.

The surgeon must examine the patient the day after surgery, initiate appropriate postoperative treatment, monitor the patient's recovery from the surgery, diagnose and treat postoperative complications, or refer the patient to an ophthalmologist better able to deal with those complications (e.g., corneal decompensation, endophthalmitis, retinal detachment, and unexplained visual loss) and perform surgical revision when appropriate (e.g., cut sutures for treatment of postoperative astigmatism). To fulfill these responsibilities, the surgeon must examine the patient periodically until he or she is confident that the patient has fully recovered from surgery, a process that usually takes 6-12 weeks.

The surgeon cannot abrogate his or her responsibility for the patient's postoperative care; however, certain components of that care can be delegated to one or more members of a team of appropriately trained professionals.

At the present time, most ophthalmologists in the United States provide all of the postoperative care in their offices. Other ways of providing postoperative care utilize optometrists, visiting registered nurses, social workers, and other health care professionals. Some optometrists provide postoperative cataract care with varying amounts of involvement. Some optometrists assume the care of the patient from the ophthalmologists soon after surgery and refer detected medical and surgical complications back to the ophthalmologist for management. Some optometrists manage postoperative complaints independently, and others become involved in the care only after the eye has healed and is ready for refraction. In certain areas of the country, the patient receives part of the postoperative care at home from ophthalmic registered nurses.

These different patterns of postoperative care and the respective roles of the operating ophthalmologist, optometrist, visiting nurse, and other health care professionals are varied, vaguely defined, and lack standardization. The panel agreed that even with these new "team" approaches, the ophthalmologist who performed the surgery remains responsible for the surgical outcomes. Therefore, in addition to the responsibilities outlined above, the ophthalmologist must do the following:

- Be aware of the patient's needs, particularly as they relate to the eye, visual function, surgery-related complications, and the coexistence of systemic diseases.
- Be aware of the type and degree of competencies required to meet the patient's needs.
- Delegate or refer care to other providers if it is deemed appropriate and in the patient's best interest.
- Educate and advise the patient about the roles and competencies of specific individuals participating in the postoperative care.
- Be aware of and acknowledge cost considerations.

There should be a shared sense of responsibility among all those participating in a patient's postoperative care and visual rehabilitation. Part of this responsibility is to maintain sufficient communication so that care is coordinated and quality of care is monitored and maintained.

The literature search did not identify any study that addressed the effect of the services provided by ancillary medical personnel (e.g., ophthalmic technicians or technologists) on the outcome of cataract surgery. This is largely because most of these providers work within the operating ophthalmologist's office under his or her direct supervision and their contributions to patient care have not been analyzed separately or as part of a team approach.

The lack of studies on the availability of emergency care is probably because there is generally no problem of availability when ophthalmologists follow their own patients. Professional ophthalmic standards require the ophthalmologist who performs the surgery to be responsible for providing emergency care or to make arrangements for another ophthalmologist to do so.

The current practice of ophthalmology residents in training providing care, including cataract surgery under appropriate supervision, is satisfactory.

## Recommendations for Research

The panel recommends that research be undertaken to determine if the outcome of surgery is influenced by the setting for cataract surgery and the type of provider of postoperative care and if the outcome is influenced by the volume of surgery performed by the surgeon.

The panel recommends that, in the best interest of the patient, research be funded to evaluate patterns of practice, including the team approach, and their impact on the quality of care provided. It also recommends that, to assure quality of care, requirements be established for all providers of postoperative care to attain clinical competence. The panel places a high priority on this recommendation, but it must be interpreted in light of the fundamental obligation of the surgeon to be responsible to the patient for postoperative care.

Patient preferences regarding the role and responsibility of the ophthalmologist who performed the surgery in the preoperative and postoperative phase should be studied.