# Guideline: Referral Pathways and Access to Care

The process of caring for a patient with functional impairment due to cataract should start when a disability is recognized. A diagnosis of cataract can be made by any of a number of health care providers, including ophthalmologists, optometrists, family physicians, and internists. However, in order to decide whether to have the cataract removed, a patient must understand the likely benefits and potential risks of undergoing cataract surgery. Such an understanding of the risks and benefits comes from a discussion with the ophthalmologist who might perform the surgery. This surgeon is responsible for ensuring that the patient understands the likely benefits and potential risks of cataract surgery in his or her case before making a decision about whether or not to proceed with surgery.

## Background

More than 1 million cataract procedures are performed under the Medicare program each year, making it the leading therapeutic surgical procedure for Americans age 65 and over. Overall, it is estimated that about 1.35 million cataract extractions were performed in the United States during 1991. Thus, how patients with functional impairment due to cataract come to receive care and how this process of interaction with the health care system influences the outcome for the individual are matters of great importance.

## Literature Review

### Methods

The purpose of the literature review was to identify and review those articles that contained information on the referral pathways for patients with functional impairment due to cataract. The referral sources to consider included self, internist, family practitioner, other ophthalmologist, other physician, other optometrist, nurse, social agency, social worker, health fairs, and nursing home screenings. (For a full description of the literature review and its results, see Appendix B in the Guideline Report.)

### Results

The results of the literature review are given here and summarized in Evidence Tables B-1 to B-3 in Appendix B of the Guideline Report.

#### Question 1: Is there evidence to support or refute an association between referral source and detection of cataracts?

A case-control study (Harrison, Wild, and Hobley, 1988) indicated that ophthalmic opticians in a district of Great Britain tended to detect and refer patients with cataract at an earlier stage in the disease than general practitioners, resulting in a greater proportion of the general practitioners' patients requiring cataract surgery. An uncontrolled case series provides descriptive information, including visual acuity and presumptive diagnosis, for referrals from an optometry clinic to various medical services in a Veterans Administration Hospital (Newcomb and Potter, 1979).

Bezan (1987) suggested that not all optometrists are referring their patients with visually significant cataract to ophthalmologists for surgical consultation. A survey of 60 Oklahoma optometrists was performed to evaluate their management of cataract patients. The survey asked: "When you examine a patient who has a cataract that is significantly affecting vision, how often do you send the patient to an ophthalmologist for a surgical consultation?" Forty-five percent referred the patient all the time, 45 percent most of the time, and 10 percent occasionally.

The Oklahoma survey measured the perceived knowledge of the optometrists about various forms of correction for aphakia. The article concludes that "the means of aphakic correction most commonly used today -- the intraocular lens (IOL) -- is the one about which optometrists feel the least knowledgeable."

Also in this survey, a concern was expressed over "one-way" referrals, "i.e., the patients are not returned to the optometrist for postsurgical refractive care." "Only 26.7 percent of the optometrists reported having their patients returned after cataract surgery all of the time." The impact of one-way referral on the optometrists' willingness to refer was not measured. The broader applicability of the results of this survey is unclear.

#### Question 2: Is there evidence to support or refute an association between referral source and timing of surgery?

No article was found to address this question.

#### Question 3: Is there evidence to support or refute an association between referral source and outcome (surgical or nonsurgical)?

Two articles provided information on outcome of surgery in relation to referral source. A case-control study (Kennedy, Brubaker, O'Fallon et al., 1985) indicated that patients with cataract who came from locales outside of the county where a tertiary care center (Mayo Clinic) is located were more likely to have diabetes mellitus and require more concurrent ophthalmic surgery procedures than cataract patients from the county in which the Mayo Clinic is located. The cases of patients referred from outside the community, therefore, were more complicated than those of community referrals. There was no significant difference in the proportion achieving 20/40 or better visual acuity after cataract surgery between community and referral patterns. A study of 57 patients referred from an optometry clinic for medical review of possible cataract (Newcomb and Potter, 1979) provides descriptive information only on the action taken by the ophthalmologist. All 57 cataract diagnoses were confirmed, and 19 (33 percent) underwent cataract surgery. However, patient outcomes are not described. The article is methodologically deficient.

#### Question 4: Is there evidence to support or refute an association between marketing techniques and detection of cataract?

#### Question 5: Is there evidence to support or refute an association between marketing techniques and timing of cataract surgery?

#### Question 6: Is there evidence to support or refute an association between marketing techniques and outcome (surgical or nonsurgical)?

Two articles provided evidence that was indirect in nature about associations between marketing techniques and detection of cataract, timing of surgery, and outcome (see Evidence Table B-2 in the Guideline Report). In a survey of members of the American Academy of Ophthalmology (Leaming, 1990), 20 percent of the respondents indicated that they felt advertising their services was a necessary practice, whereas a survey of ophthalmologist-members of the American Society of Cataract and Refractive Surgeons, a cataract surgeon society, indicated that 27 percent felt advertising was necessary to their practice (Leaming, 1988). Both surveys suffered from low response rates, thereby making their broader applicability unclear.

#### Question 7: Is there information on cost and/or cost-benefit issues?

There was no direct information on cost and/or cost-benefit issues in referral for management of cataract. One article (Roberts and Zalta, 1988) indicated that, in comparison to actual costs obtained from claims data, if physicians accepted Medicare reimbursement for cataract surgery, costs would be considerably reduced (see Evidence Table B-3 in the Guideline Report). However, the applicability of the study is limited to those settings where Medicare reimbursements constitute the sole reimbursement for cataract surgery.

### Conclusions From the Literature Review

No definite conclusions can be reached as a result of this review. Two papers, however, suggest that referral rates could be influenced by the referral source. General practitioners in Great Britain tended not to refer patients until surgery was imminent. Optometrists surveyed in Oklahoma tended not to routinely refer patients with symptomatic cataracts.

## Conclusions of the Panel

The issues surrounding referral for management of functional impairment due to cataract are complex. Although they are integral to fundamental aspects of the quality of care, they have received, so far, very little attention in the medical or sociologic literature. From the patient's perspective, even if surgery is not immediately considered, the purpose of referral is to ensure that cataract is the cause of the decreased vision and that other causes are not present. A variety of ocular, neurologic, and systemic diseases may cause impairment in the presence of lens opacities. They may arise in patients with a known diagnosis of cataract. Some of these conditions are treatable if diagnosed in a timely manner.

The process of referring a patient with functional impairment due to cataract for care starts when a visual disability is recognized. A diagnosis of cataract can be made by any of a number of health care providers, including ophthalmologists, optometrists, family physicians, and internists. However, in order to decide whether to have the cataract removed, a patient must understand the likely benefits and potential risks of undergoing cataract surgery. Such an understanding of the risks and benefits comes from a discussion with the ophthalmologist who might perform the surgery. This surgeon is responsible for ensuring that the patient understands the likely benefits and potential risks in his or her case before the patient makes a decision about whether to proceed with surgery. Some conditions require cataract surgery for their treatment even though the cataract is not the vision-limiting factor. Other conditions will preclude any benefits from cataract surgery.

It is in the patient's best interest that recognition of a visual disability lead to consultation with an ophthalmologist who has the requisite skills to confirm the diagnosis and to provide the appropriate treatment. Patients appear to reach the surgeon through a variety of means, including self-referral; referral by family or friends; patients of eye care specialists; other physicians, including family practitioners, primary care physicians, internists, and other specialists; and other ophthalmologists, optometrists, opticians, ophthalmic registered nurses, registered nurses, or nurse practitioners. In many instances, patients develop cataracts while under the routine eye care of other ophthalmologists or optometrists. These patterns are well established throughout the country and appear to provide a satisfactory referral mechanism for many patients. However, as a result of the review of recent data (published after the December 31, 1990, cutoff date for the systematic review of the literature), the panel is concerned that these patterns of referral may not apply universally. For example, certain circumstances; economic factors; social issues, particularly those of a racial nature; language barriers; and the uneven distribution of medical resources may inhibit appropriate referral and access to care (Javitt, McBean, Nicholson et al., 1991; Sommer, Tielsch, Katz et al., 1991).

## Recommendations for Research

The issues addressed in this literature review, particularly the impact of self-promotion by the ophthalmologist and optometrist, and the influence of different routes of referral on surgical rates and outcomes are also important considering that large variations in cataract surgery rates within small geographic areas have been reported (Holahan, Berenson, and Kachavos, 1990). Therefore, the panel recommends that these aspects of the referral mechanism be subjected to further inquiry.

In addition, several other issues related to access to care and referral are pertinent because of the impact that they may have on overall quality of care, surgical rates, and the appropriate use of the surgical procedure. They were not addressed in the literature review and require targeted research. These are as follows:

- Optometric-ophthalmologic referral relationships with a formal or informal contractual basis.
- Mass screening in nursing homes and in other venues by ophthalmologists and optometrists to identify patients with cataract.
- Ophthalmologic or optometric ownership of surgery centers.
- Managed-care organizations and cost-containment policies of managed-care organizations.
- New reimbursement policies for Medicare patients.
- Proposed preferred provider organizations for patients with cataract.