# Overview

## Guideline Development Process

The Agency for Health Care Policy and Research (AHCPR) was established on December 19, 1989, by the Omnibus Budget Reconciliation Act (Public Law 101-239) as one of the agencies of the Public Health Service. The purpose of AHCPR is to enhance the quality, appropriateness, and effectiveness of health care services and access to such services. As specified by Section 911 of the Act, the Office of the Forum on Quality and Effectiveness in Health Care was established within AHCPR. The Forum was directed to facilitate the development and periodic review and updating of:

Clinically relevant guidelines that may be used by physicians, nurses, social workers, educators, and health care practitioners to assist in determining how diseases, disorders, and other health care conditions can most effectively and appropriately be prevented, diagnosed, treated, and managed clinically. (Section 912)

The legislation that established AHCPR mandated that guidelines on at least three clinical conditions be completed and submitted to Congress by January 1, 1991, and that a report evaluating the effects of these guidelines be submitted to Congress in 1993. The selection by AHCPR of clinical conditions for guideline development is to be based on the following considerations:

- Adequacy of scientific evidence related to a topic.
- Prevalence of the clinical condition.
- Morbidity and mortality associated with the condition
- Possibility for prevention of the condition.
- Potential for benefit.
- Variability in practice.
- Importance of the condition to the Medicare and Medicaid populations.
- Costs of the condition to patients and other payers.

Guidelines are developed by panels of qualified experts and health care consumers convened by AHCPR. Panel chairs are selected from nominations submitted to AHCPR by interested organizations of health care practitioners. Panel members are selected from nominations encompassing a broad range of interested organizations and individuals, including health care professional societies and consumer organizations. The American Academy of Ophthalmology has demonstrated the feasibility of developing such a guideline with the publication of "Cataract in the Otherwise Healthy Adult Eye" in its Preferred Practice Pattern series.

General methods for guideline development have been specified by AHCPR. They require that "all scientific evidence is considered, the consequences of different options are weighed, and the scientific evidence and subjective judgments supporting the chosen options are described explicitly." Although it is intended that the guidelines will rely on scientific evidence as much as possible, it is also recognized that professional judgment and group consensus may also be used during the process when insufficient empirical evidence is available to evaluate the safety or effectiveness of treatments or procedures. The guidelines must be explicit as to when conclusions are derived from evidence and when professional judgments are being made. In addition to summarizing the available evidence, panels are expected to identify areas where additional research is needed.

The process of developing a guideline based, first, on knowledge derived from the relevant literature and, second, on expert opinion involved several stages. The panel convened by AHCPR to study cataract was provided with the general topic for guideline development. The specific issues to be addressed were subsequently defined by the panel at its initial meeting. In consultation with the Ad Hoc Literature Review Group, the guideline panel identified the scope of the guideline and the topics to be researched in the literature review. The panel chose to focus, in general, on functional impairment of the patient with cataract and, in particular, on improvement in function as a result of treatment for the condition.

After consultation with the director of the literature review, the methodology consultant, and panel members, the panel chair appointed literature review teams for each topic. These teams consisted of content and methodology experts, content and methodology form developers, and literature reviewers. In order to meet the charge to consider all scientific evidence, the panel initiated a systematic review of the medical literature relating to cataract. The specific methods used in this review are described in detail in this chapter's methodology section and in Appendix A of the Guideline Report. In general, the National Library of Medicine planned the literature search, with ad hoc notification of additional articles by the panel members and medical community also included in the plan in order to maximize ascertainment of all available data. The literature review teams prepared the results in a series of scientific reports (see the appendices in the Guideline Report), which were submitted to the panel to assist in the guideline development. The panel wrote and approved the guideline, using as resources the report of the literature review, its own expertise in the areas under consideration, and information obtained as a result of presentations made to open forums as well as informal communications with the panel chair and panel members. Methods used in the guideline development, including the literature review portion, are comparable across all AHCPR-sponsored guideline panels.

As noted earlier, when empirical evidence was not available for a particular question posed by the cataract guideline panel, panel members made informed judgments and agreed on them using the consensus process. Thus, although scientific evidence from the literature was the primary source for the conclusions drawn by the panel in writing the guideline, it was not the only source. Consideration of the opinions of the experts on the panel was necessitated not only by the absence of published data regarding specific issues, but also by the fact that, in some instances, the results available in the published literature are based on clinical practices and surgical techniques that have since been updated by other approaches and are infrequently or no longer practiced. The basis for conclusions presented herein will be stated as required. The guidelines developed by each panel are dynamic documents. As with any review of available evidence, they are necessarily at risk of being outdated by the time they are published. AHCPR plans to review the guidelines at regular intervals and to update them when significant advances warrant.

## Organization of the Clinical Practice Guideline

Functional impairment due to cataract in adults is a broad topic. The condition is of particular importance for two reasons. First, it is prevalent in the U.S. population, and, second, surgery for the condition is a significant item in the Medicare budget. It is the most commonly performed surgery in the elderly population, with an estimated 1.35 million procedures being performed every year (Health Care Financing Administration, 1990, 1991).

Functional impairment due to cataract refers to lost or diminished ability to do any of the following:

- Perform everyday activities -- bathing, dressing, eating, using the toilet, walking, preparing meals, doing housework, doing laundry, shopping, taking medicine, getting around outside, driving or using other transportation, managing money, and using the telephone.
- Participate in hobbies or other leisure-time activities (e.g., reading, watching television).
- Work in one's occupation.

Although the word cataract immediately raises in most minds the question of surgery, the issues addressed in this guideline are much broader. From the perspective of the body's five senses, a cataract can cause a decrease in visual function that can be classed as a visual disability. It is important to recognize the impact of this disability on the individual's ability to function autonomously and to perceive self as healthy. Maintenance or restoration of autonomy through appropriate treatment to remove the disability therefore becomes the goal of the guideline.

To facilitate this broad approach to the care of persons with functional impairment due to cataract, this guideline is divided into sections. The next three sections of this overview cover ethics, the natural history of cataract and functional impairment due to cataract, and risk factors for cataract. Ethical issues are an integral component of the delivery of health care. In 1983, the President's Commission for the Study of Ethical Problems in Medicine stressed the need for ethical issues to receive consideration in the formation of health care policy (President's Commission for the Study of Ethical Problems in Medicine and Biomedical and Behavioral Research, 1983). The sections on the natural history of cataract and functional impairment and risk factors provide the basis for our understanding of the disease and its impact on the patient and discuss the interventions that eventually might be undertaken to deal with preventable causes. They are intended to be used as background information for the reader and were not written under the same rigorous constraints of literature inclusion criteria and review as the remaining sections. (See Appendix A in the Guideline Report and this chapter's methodology section.)

The second chapter of this report discusses referral pathways and access to care. Access to care has also been deemed a critical issue by the President's Commission, which wrote: "In examining the special nature of health care, we discern in our country traditional commitment to fairness and ethical obligation that all Americans have access to an adequate level of health care without the imposition of excessive burden" (President's Commission for the Study of Ethical Problems in Medicine and Biomedical and Behavioral Research, 1983). In the context of the current debate, access to care remains a critical issue 9 years after this report.

The third chapter addresses changes in the setting of care for cataract and how these new settings and organizations can have a crucial impact on the outcome of the patient's encounter with the health care system. Cataract surgery has undergone a major transformation in the past few years, having been transferred almost entirely to the outpatient setting. This has been coupled with incredible technological advances in surgical techniques. In addition, other health care providers (e.g., optometrists, anesthesia providers, home health nurses, social workers) are more visibly involved in certain components of the care of these patients as part of the health care team.

The fourth chapter examines the suitability and applicability of a series of preoperative tests used for a variety of purposes in management of the patient with cataract.

The fifth chapter discusses various aspects of nonsurgical treatment and surgery, including the indications for surgery that are to be used in defining the suitability of a patient for surgery. It also contains sections on preoperative evaluation, anesthesia, surgical management and complications, and surgery on the second eye. Each of these deals separately with important aspects of the surgical management of cataracts and provides a guideline, as far as is known, for the most appropriate way to approach patients progressing toward and having surgery.

The sixth chapter deals with postoperative care and its components. The seventh chapter deals with the issue of rehabilitation and the numerous factors that are involved in successful rehabilitation. The eighth discusses the management of functional impairment due to posterior capsular opacification (PCO) and the indications for and performance of Nd:YAG capsulotomy for PCO. YAG laser capsulotomy is the most commonly used technique for treating PCO. Nd and YAG are abbreviations that stand for neodymium and yttrium aluminum garnet.

It will become apparent on perusal of this guideline that many of the important questions raised and subjected to literature search have no ready answers. This does not necessarily mean that the practices currently followed in the United States are of poor or inferior quality. Rather, in many instances, it means that the topic has not been studied in a formal way. When the topic is of sufficient importance, and as yet not settled, the panel recommends that research be undertaken to provide scientifically definitive answers to resolve the issue. The organization of the Clinical Practice Guideline is designed to facilitate revision as new information comes to hand.

## Ethics: The Relationship Between Caregiver and Patient1

[1] Prepared by Edwin Casem, MD, FACP, and Denis O'Day, MD, FACS. As used here, the term "appropriate ethical conduct" refers to conduct within the social relationships between lay people and health professionals that is built on complex layers of trust. The bond between caregiver and patient is, therefore, a special one, to be regarded as a covenant rather than a contract. A covenant is considered inherent to the caregiving role. It exists independently of, and effectively predates, individual relationships with patients. The principal goal of this bond of trust is beneficence- acting always in the patient's best interests (whether to improve health, to relieve suffering, or merely to provide comfort). These interests are determined by ongoing discussions with the patient in the context of medical diagnosis, available therapies, and the caregiver's reasonable judgment. The bond is also expressive of certain primary professional virtues, including loyalty, fidelity, confidentiality, respect, and charity - virtues that are expected of the caregiver in all professional dealings with patients. When a person with impaired vision requests or needs help, the covenant requires that these needs be met with competence and compassion.

Despite the emphasis on beneficence as essential to the motivation of the caregiver, this covenant should not be construed as imposing passivity on the patient or encouraging an attitude of condescension in the caregiver. Rather, the relationship is one of interdependence. The patient, though of diminished autonomy as a result of the illness, nonetheless has authority in the relationship. This authority arises by virtue of the patient's experience of the illness that is unique and essential to the diagnosis and treatment and by virtue of the contribution to the caregiver's and society's developing knowledge of the condition. This mutual partnership demands that the caregiver listen to and honor the experience of the patient.

When guidelines are developed, therefore, they must embody the covenantal motivation; no legislative enactment or legal contract can suffice. Caregivers are bound to the communities they serve by responsibilities inherent to the service role. Moreover, in such a covenant, the individual's and the community's needs must be carefully balanced, keeping in mind that the individual's welfare takes priority and must therefore be protected from extraneous appeals to social welfare and societal concerns. At the same time, attention should be given to providing sensitive and effective care at reasonable cost. Although there are limits on what individuals can demand, it is reasonable to propose that it would be ethically unacceptable to ration cataract treatment so that some individuals in valid need of surgery would be excluded.

The overall goal for the health care professionals is to provide quality eye care to every person needing it, such that every person in valid need would be able to receive both cataract extraction and intraocular lens (IOL) implantation when indicated and the appropriate required aftercare.

For each caregiver, the covenant with the patient includes the following elements:

- Effective and sensitive communication -- including skillful talking with patients and listening to the concerns of each patient.
- Appropriate education about the nature of the impairment, the proper treatment and alternatives, the prognosis, risks and benefits, and understandable rationales and explanations of needed tests and their respective results.
- Intervention at the proper level of competence.
- Continuity of care, including coverage 24 hours a day, 7 days a week, when needed, with adequate mechanisms for instructions to the patient on how to obtain care.
- Appropriate consultation with and referral to other ophthalmologists, optometrists, opticians, low-vision specialists, etc.
- On request of the patient, a full and accurate rendering of the patient's records.
- Timely and effective review of the results of consultation and laboratory tests, along with any appropriate action required.
- For all patients, and perhaps especially those who do not respond to treatment, provision of support, counseling, rehabilitative and social services, and other appropriate referrals. Preoperative assessment must identify the patient's aftercare needs and any particular obstacle to a successful outcome that would require special attention or referral.

While an attempt is being made to provide care at reasonable cost, priority must be given to quality eye care for all patients. Caregiver responsibility means that the commitment to care comes before provider convenience or costs. The first, or intrinsic, good is better visual functioning for the patient, but other goods are also achieved. Caregivers who meet the covenant responsibilities described herein earn and deserve reasonable compensation; beneficence does not preclude appropriate, competent, and reasonably compensated cataract surgery. New discoveries advance the understanding of cataract formation, leading to improved diagnosis and new ways to prevent their development. All such outcomes are welcomed and promote quality patient care and can issue from the first, intrinsic good of improving the patient's vision.

In this context, the panel was concerned by reports of some eye care providers using high-powered marketing to recruit patients who might not need cataract surgery and of ophthalmologists who do not spend appropriate time in evaluating the patient preoperatively, explain the potential risks and benefits of surgery, or assume appropriate responsibility for their postoperative care. Such conduct violates the standard of cataract care in both letter and spirit.

Protection and/or restoration of good vision for the elderly is a shared provider goal. It can make the difference for walking or driving safely, staying in touch through reading or watching television, retaining the ability to keep one's own books and to write, and enjoying the subtleties of communication with family and friends. The direct link between vision and independence and quality of life makes it one of our most precious attributes. Improving vision for the elderly is not only possible with the skills of professional providers but of the highest priority.

## Natural History of Cataracts: The Relationship to Functional Impairment 2

[2]This section on the natural history of cataracts was prepared by Sheila West, PhD, and contains findings from the panel's literature review. The specific literature review search questions for this category were:

- Question 1.
- What is the natural history of idiopathic cataract, including demographics, rate of progression, impact on quality of life, and complication rates if untreated?
- Question 2.
- What is known of epidemiology, including prevalence?
- Question 3.
- What is known of risk factors and opportunities for minimizing the risk of developing cataract?

See the methodology section for more information on the literature review.

Cataract remains the leading cause of blindness worldwide, with an estimated 17 million blind (Foster and Johnson, 1990). The burden of this avoidable cause of vision loss falls primarily in less developed countries, where less than 20 percent of cataract patients are estimated to receive surgery (Kupfer, 1984). In the United States, surgery is perceived as generally available, and cataract surgery is the most common surgical procedure performed under Medicare. Nevertheless, cataract remains an important cause of visual loss in U.S. populations surveyed for causes of blindness (Dana, Tielsch, Enger et al., 1990; Sommer, Tielsch, Katz et al., 1991).

As the U.S. population ages, there is an urgent need to develop plans for the provision of eye care services to manage the increasing numbers of age-related eye diseases, yet there are few data on incidence or natural history of cataract. Such data are vital for health planners, for clinical trials of potential anticataract agents, and for trials on the modification or prevention of factors that may increase the risk of cataracts.

### Definition of Cataract

One significant problem in reviewing existing data is the varying definitions of "cataract" that are used in the literature. Different definitions are appropriate and depend on the research or program question that is being addressed. For epidemiologic studies of risk factors, it is important to identify the earliest lens changes that represent onset of disease. Thus, one definition of cataract is the presence of lens opacities. These lens opacities are objective changes and, as such, can be evaluated and recorded, and they may or may not have associated visual impairment or functional consequences (Adamsons, Munoz, Enger et al., 1991; Chylack, Leske, Sperduto et al., 1988; Leske, Chylack, Sperduto et al., 1988; West, Rosenthal, Newland et al., 1988). Thus, this definition may not be useful for addressing the visual or functional consequences of cataract.

A second definition frequently used is a lens opacity that causes, or is accompanied by, loss of visual acuity (Adamsons, Munoz, Enger et al., 1991; Hiller, Sperduto, and Ederer, 1983; Kahn, Leibowitz, Ganley et al., 1977). This definition has been used in prevalence surveys to identify lens opacities that are severe enough to interfere with vision. A problem with this definition is that other causes of visual acuity loss besides (or in addition to) the lens opacity must be excluded. Moreover, advanced lens changes, particularly cortical changes, can be present with no accompanying loss of acuity. Nevertheless, if data are needed on visually significant cataract, some component of loss of visual function must be included in the definition. The level of visual acuity loss may be modest (in Framingham, best visual acuity of 20/30 or worse was selected as a cutoff [Kahn, Leibowitz, Ganley et al., 1977]). However, current discussions in the ophthalmic literature report that visual acuity may not be the only appropriate vision function parameter to measure in cataract, with loss of contrast sensitivity and glare representing visual consequences more sensitive to cataractous change (Drummond, 1990).

A third dimension of cataract relates to the functional consequences of lens opacification for everyday activities. Clinicians are well aware of patients with 20/40 cataracts who report no functional disability associated with their ocular status, although other patients with seemingly good vision have curtailed driving activities. The focus of this document is the care of the patient with functional disability due to cataract.

Each of these different approaches to the definition of lens opacity or cataract has relevance in the context of the research or program focus in which it is used. However, when attempting to describe the "natural history" of cataracts, one must be precise in the definition of cataract and be aware that the implication of using any one definition will alter the epidemiologic picture. Moreover, there will also be large differences in the epidemiology of the different cataract types.

### Prevalence Data

Population-based data on prevalence of cataract in the United States aare few. Three sources that will be reviewed are the Framingham Eye Study, the National health and Nutrition Examination Survey, and the Watermen Study.

The prevalence of lens opacity and cataract was determined in the Framingham Eye Study during eye examinations carried out from 1973 to 1975 (Kahn, Leibowitz, Ganley et al., 1977; Sperduto and Seigel, 1980). For determination of cataract, the definition specified lens opacities accompanied by visual acuity of 20/30 or worse. Aphakics were included in both lens opacities and cataract groups. Table 1-1 shows that age-related lens opacities were already present in 42 percent of those aged 52-64, although only 5 percent had visual impairment. By age 75-85, almost all the population had some opacities, and nearly half either had some visual loss or were aphakic.

Table 1-1. Percent of Persons with Lens Opacity and Cataract Based on Different Surveys, by Age

Source | < 35 | 35-44 | 45-54 | 55-64[1] | 65-74 | 75-84[1] | 85+
Framingham[1] (Source: Kahn, Leibowitz, Ganley et al., 1977)
Lens opacities | - | - | - | 41.7 | 73.2 | 91.1 | -
Cataract | - | - | - | 4.5 | 18.0 | 45.9 | -
NHANES[2] (Source: Leske and Sperduto, 1983)
Lens opacities | - | - | 12.2 | 27.6 | 57.6 | - | -
Cataract | - | - | 2.6 | 10.0 | 28.5 | - | -
Watermen[3] (Source: Taylor, West, Rosenthal et al., 1988)
Lens opacities | 1.8 | 2.7 | 5.7 | 37.0 | 72.1 | 94.2 | 100.0
Cataract | - | - | - | 5 | 25 | 59 | -

[1] Both sexes combined. Population ranged from age 52 to 85, so those age 85 are included in last grouping, and those age 52-54 are among the 55 -64 group; white residents only.

[2] Both sexes and all races combined.

[3] Men only. Population ranged from age 30 to 94. Only those age 50-85 were studied for cataracts, defined as lens opacities accompanied by visual acuity of 20/30 or worse.

The National Health and Nutrition Examination Survey (NHANES) was conducted on a probability sample of the U.S. civilian noninstitutionalized population. The examinations were conducted by 91 ophthalmology residents scattered across the country, so estimates of lens opacities must be interpreted with caution, as standardization was exceedingly difficult. Cataracts were defined in NHANES as lens opacities accompanied by visual acuity of 20/25 or worse (see Table 1-1). The higher proportion found to have cataract in NHANES compared with the Framingham study may be due to higher visual loss criteria in Framingham, regional differences in NHANES, or differences in diagnosis (Leske and Sperduto, 1983). The last reason may well explain the significant differences in lens opacities between the two studies.

In 1984-85, clinical and photographic assessment of the lens was performed on 831 fishermen, or "watermen," in Maryland (Taylor, West, Rosenthal et al., 1988). Although this was not strictly a population sample but rather an occupational sample, in most of the small fishing communities visited, all the men were enrolled in the study by virtue of their occupation. The lens opacity rates and cataract prevalence were not dissimilar from those found in the previous studies (see Table 1-1), despite differences in methodology of assessment. Cataracts associated with visual impairment become prevalent after age 60-65.

In summary, although lens opacities are often found in those under age 45, there are no prevalence data on functional cataract to compare with the data on lens opacities or early cataract.

There are few data on the population-based prevalence of specific subtypes of cataract. Data from the Framingham Eye Study included information on specific subtypes of lens opacities, although 65 aphakic subjects were not included because the subtype was unknown (Sperduto and Hiller, 1984). Many of these may have been posterior subcapsular (PSC) cataract opacities. Although they are rare in population surveys, they are disproportionately represented in surgical series (Adamsons, Munoz, Enger et al., 1991). As shown in Table 1-2, nuclear opacification was the most frequent opacity recorded, either as pure or mixed opacity. Data from NHANES also included subtype of cataract, although the number of examiners and lack of standardization in this study are serious limitations to the interpretation of findings on subtype (Hiller, Sperduto, and Ederer, 1986). No age-specific data have been published from this source, but over the entire population, nuclear cataract, alone or in combination, was the most common type. The same pattern of subtypes was observed in the watermen population, where nuclear was the most common type, except after age 80, when mixed opacities predominated (Adamsons, Munoz, Enger et al., 1991).

Table 1-2. Percent of Persons with Cataract Types Based on Different Prevalence Surveys, by Age

Source | Nuclear | Cortical | PSC | Mixed
Framingham[1] (Source: Sperduto and Hiller, 1984)
< 35 | - | - | - | -
35-44 | - | - | - | -
45-54 | - | - | - | -
55-64 | 5.7 | 4.6 | 2.2 | 5.4
65-74 | 18.9 | 9.9 | 2.4 | 17.9
75-84 | 30.0 | 5.8 | 1.3 | 36.5
85+ | - | - | - | -
Watermen[1](Source: Adamsons, Muñoz, Enger et al., 1991
30-39 | 0 | < 1 | < 1 | < 1
40-49 | 4.1 | 0 | 0 | 0
50-59 | 11.5 | 3.6 | < 1 | 2.4
60-69 | 33.0 | 7.4 | 0 | 15.3
70-79 | 45.7 | 7.6 | 0 | 33.3
80+ | 38.9 | 5.6 | 0 | 55.6
Surgical Series[2](Source: Adamsons, Muñoz, Enger et al., 1991
< 50 | 5.6 | 0 | 77.8 | 16.7
50-59 | 16.1 | 3.0 | 45.2 | 35.5
60-69 | 12.2 | 12.2 | 31.7 | 43.9
70-79 | 35.1 | 7.0 | 5.3 | 52.6
80+ | 19.4 | 8.3 | 8.3 | 63.9

[1] Data are for lens opacities.

[2] Data are based on a series of 183 cataract surgery patients.

The contrast with the types of cataract that actually present for surgery is interesting, in that among the younger ages, PSC was the predominant cataract type (Adamsons, Munoz, Enger et al., 1991). Most of the mixed cases, at least in this series, also included PSC, suggesting that PSC is a significant cause of functional cataract, if not a prevalent one.

### Incidence and Progression

Understanding the natural history of lens opacities and cataract will depend on knowledge of the incidence of lens opacities and progression of opacities to cataracts in the population. Such data are currently unavailable, although some longitudinal studies are now under way. Clearly, there is a need to acquire data on age-specific incidence of cataract, especially functionally significant cataract, for purposes of planning eye care delivery for the older population in the United States and other countries. The sparse data that are available and summarized here are based on statistical projections of population studies, prospective evaluations of ill-defined case series that used untested methodologies, and abstracts from meetings reporting current approaches.

Based on the Framingham Eye Study prevalence data, Podgor and associates (Podgor, Leske, and Ederer, 1983) constructed age-specific incidence estimates for lens opacities and cataracts Table 1-3. The authors note the possibility that the incidence data for cataracts are underestimates because the definition of the cataract included the constraint that the cataract must entirely account for vision loss to 20/30 or worse. Thus, the prevalence estimates, which are the starting parameters in the model, may not include cataracts that occurred in combination with other diseases that may also contribute to visual loss. Although an estimated 10-37 percent of the population may develop early lens opacities, the incidence of visually impairing cataract is lower, according to this model.

Table 1-3. Age-Specific 5-Year Incidence of Lens Opacities and Cataracts: Framingham Eye Study

Age | Lens Opacities (Percent) | Cataracts (Percent)
55 | 10 | 1
60 | 16 | 2
65 | 23 | 5
70 | 31 | 9
75 | 37 | 15

Source: Podgor, Leske, and Ederer, 1983.

When Podgor's methodology is applied to the Watermen prevalence data, the incidence of specific types of opacities can be calculated. The incidence for cortical and nuclear opacities within comparable age groups is equal to or slightly higher than the incidence of total lens opacity in the Framingham data (Table 1-4). In both populations, the incidence appears to increase with age, with some suggestion of leveling off in the oldest age group (see Table 1-4). Clearly, actual longitudinal data are needed in populations before conclusions on incidence can be drawn.

Table 1-4. Age-Specific Incidence of Cortical or Nuclear Lens Opacities: Watermen Eye Study [1]

Age | Cortical (Percent) | Nuclear (Percent)
30-39 | 1 | < 1
40-49 | 3 | 2
50-59 | 8 | 12
60-69 | 17 | 32
70-79 | 32 | 51
80+ | 32 | 55

[1] The opacities are not mutually exclusive.

Source: S. West, personal communication.

### Conclusions

There is a significant need for a sensitive and reliable system to detect cataract change for longitudinal studies (Munoz, West, Wang et al., 1991). Several methods have been proposed, and all are prone to measurement error, which in some cases can result in equal amounts of "improvement" and progression. Data from case series suggest that progression rates of opacities may be higher than the incidence of new opacities (Chylack, Leske, Khu et al., 1989; Magno, Datiles, Sperduto et al., 1991). This observation needs to be studied in population series to confirm the validity.

More information on incidence and progression will be generated from currently funded research projects on risk factors for lens opacities. However, few of the current studies are designed to evaluate the incidence of cataracts that cause functional disability or to determine the progression of cataracts from having no functional consequences to those causing functional loss. This research is clearly necessary to evaluate the likely onset of functional loss from lens opacities and the probable need for cataract surgery in the future.

Such studies are difficult to undertake for at least two reasons. First, instruments to measure the functional impact of cataracts are in the developmental stage. Many instruments on functional status do not include measures likely to be affected by decreases in vision or glare. Special instruments designed to assess specific functional loss attributable to vision have not been completely validated. Additionally, comorbid conditions among those with cataract need to be assessed, as a decrease in vision may be exacerbated by the presence of other diseases to produce functional loss; conversely, any benefit from surgery may be mitigated by the presence of other conditions (Elam, Graney, Applegate et al., 1988). Despite these difficulties, there is growing recognition by policymakers that functional outcome and quality-of-life issues are important determinants of health care policy priorities (Drummond, 1990).

## Prevention and Risk Factors

Approaches to cataract control have centered on the timely and cost-efficient provision of surgical services to those most in need (Taylor and Sommer, 1990). However, if risk factors for cataracts could be identified and strategies for prevention implemented, the volume of cataract blindness would diminish. For example, it has been estimated that if a factor could be found that simply delayed the onset of cataract by 10 years, the number of cataract operations would decline by 45 percent (Kupfer, 1984). The purpose of this review is to summarize the data on known risk factors for cataract.

### Ultraviolet-B Radiation

A number of ecologic studies have shown a higher prevalence of cataracts or lens opacities in populations living in areas with high ultraviolet-B (UV-B) radiation (Brilliant, Grasset, Pokhrel et al., 1983; Hiller, Sperduto, and Ederer, 1983; Hollows and Moran, 1981; Taylor, 1980). The consistency of the association despite different populations and study methodologies strengthens the likelihood that UV-B is a causal factor. Recent studies using measures of personal exposure to UV-B have shown that cortical opacities and PSC opacities are related to cumulative lifetime exposure to UV-B (Bochow, West, Azar et al., 1989; Taylor, West, Rosenthal et al., 1988). These studies have also shown the important effect of sunglasses and hat use in reducing ocular exposure to UV-B. However, because the amount of risk attributable to UV exposure is unknown, it is not possible to estimate the effect of such protection on the likelihood of developing a cataract that will require cataract surgery.

### Diabetes

Diabetics appear to be at higher risk for cataract compared with nondiabetics (Ederer, Hiller, and Taylor, 1981). The excess mortality associated with cataract patients is confined to those with diabetes (Podgor, Cassel, and Kannel, 1985), and diabetics with cataracts appear to be at greater risk of death than those without cataracts (Cohen, Neil, Sparrow et al., 1990). The mechanism of action for "sugar cataracts" was described in several reviews (Kinoshita, 1990; Kinoshita, Fukushi, Kador et al., 1979). PSC, cortical, and mixed opacities were the types most commonly associated with diabetes in case-control studies (Bochow, West, Azar et al., 1989; Leske, Chylack, and Wu, 1991).

### Drugs

Several drugs have been proposed as potentially cataractogenic, although detailed studies are few. The association between corticosteroid use and risk of PSC cataract is well known (Black, Oglesby, von Sallman et al., 1960; Bochow, West, Azar et al., 1989; Italian-American Cataract Study Group, 1991; Leske, Chylack, and Wu, 1991), although controversy remains over the role of individual susceptibility and dose or duration of steroid therapy. The possible protective effect of aspirin was not confirmed by data from several studies (Peto, Gray, Collins et al., 1988; Seddon, Christen, Manson et al., 1991; Seigel, Sperduto, and Ferris, 1982; West, Munoz, Newland et al., 1987). It is unlikely that aspirin in prophylactic or sporadic doses is protective against cataract formation.

Diuretics have been implicated in cataractogenesis (Clayton, Cuthbert, Seth et al., 1984; Klein, Klein, and Moss, 1985; Mele, Alston, Moorman et al., 1990). However, it is difficult to disentangle the effect of the diseases for which these drugs are prescribed from the effect of the drugs themselves. In one study with longitudinal data on thiazide use, the risk of cortical opacities was highest in individuals using thiazides for 4 or more years, but they also had hypertension of long duration (Mele, Alston, Moorman et al., 1990).

Major tranquilizers, particularly phenothiazines such as chlorpromazine, were associated with increased risk of cataract (Clayton, Cuthbert, Seth et al., 1984; Collman, Shore, Shy et al., 1988). Another study with longitudinal data on phenothiazine use was equivocal, with no evidence of a dose-response relationship with cataract extraction (Isaac, Walker, Jick et al., 1991). Patients with decreased vision, including vision loss from cataract, are known to be depressed (Elam, Graney, Applegate et al., 1988). Association of the use of these drugs in the recent past with cataracts (particularly with cataract extraction) may be more reflective of the depressive consequence of vision loss.

### Smoking

Risk of nuclear opacities from smoking was first reported in 1989 (est, Munoz, Emmett et al., 1989) and was confirmed in other studies (Christen, Manson, Seddon et al., 1992; Flaye, Sullivan, Cullinan et al., 1989; Hankinson, Willett, Colditz et al., 1992; Leske, Chylack, and Wu, 1991). In addition, there may well be an increased risk of developing PSC cataract (Christen, Manson, Seddon et al., 1992; Hankinson, Willett, Colditz et al., 1992). Exsmokers appeared to have a lower risk than current smokers, regardless of amount smoked.

### Diarrhea

Another factor of potential importance is the possible effect of severe diarrheal episodes on cataractogenesis. This may be of greater relevance in countries where diarrhea is endemic and more severe than in the United States. The data, however, are conflicting: one study found a 21-fold increased risk of cataract associated with two or more episodes of severe diarrhea (Minassian, Mehra, and Jones, 1984); several other studies have found no association (Bhatnagar, West, Vitale et al., 1991; Mohan, Sperduto, Angra et al., 1989).

### Alcohol

Several studies have now reported an association between heavy drinking and cataracts (Clayton, Cuthbert, Duffy et al., 1982; Harding and van Heyningen, 1989; Munoz, West, Tajchman et al., forthcoming; van Heyningen and Harding, 1988). One study found a fourfold increased risk of PSC cataract in those who were consuming one drink per day on average. As alcohol consumption is fairly ubiquitous worldwide, this hypothesis deserves further investigation in other settings.

### Antioxidant Vitamins

Nutritional status and cataracts present a complex and confusing picture. The data from human studies are sparse and incomplete. One problem is the high correlation among dietary intakes of various nutrients. For example, early work in India suggested diets low in protein may be a risk factor for cataract; however, these diets may be low in a number of micronutrients (such as riboflavin) as well (Chatterjee, Milton, and Thyle, 1982).

Current studies are suggestive of an increased risk of cataract associated with low antioxidant status (Jacques, Chylack, McGandy et al., 1988; Jacques, Hartz, Chylack et al., 1988; Leske, Chylack, and Wu, 1991; Vitale, West, Hallfrisch et al., 1991). However, the type of cataract associated with low antioxidant status varies from study to study, and the constituents of the "antioxidant indices" vary, making the results of this body of work inconclusive. It is premature to recommend vitamin ingestion as a control strategy until further research is more definitive (West, 1991).

### Conclusions

The last 5 years have produced a wealth of data on risk factors for cataracts. Cataract is clearly a multifactorial disease, and different factors are associated with different types of opacities. The findings are encouraging for those risk factors at which simple, preventive strategies might be targeted, such as decreasing sun exposure, increasing antioxidant vitamin use, or smoking cessation. For example, use of UV-absorbing glasses and a hat would reduce exposure to UV-B light. However, because the amount of risk attributable to UV exposure is unknown, it is not possible to estimate the effect of such protection on the likelihood of developing a cataract that will require surgery.

Further research is needed to develop and assess the impact of strategies designed to reduce or retard the development of cataract. The potential saving in human suffering and cost that could result from preventing or retarding cataract development and progression, including the possibility of precluding development of functionally significant cataract in a large proportion of elderly, is enormous. At this time, management guidelines on reducing the risk of cataract cannot be provided.

### Cost of Care

The panel found no published data regarding the frequency with which various preoperative, intraoperative, and postoperative services are provided in connection with extraction of a cataract or regarding the cost of those services. The panel, therefore, asked the AHCPR-funded Cataract Patient Outcomes Research Team (PORT) to assess both the content and cost of an episode of cataract surgery through analyses of a sample of 1986-87 Medicare claims data (for beneficiaries 65 years of age or older). In addition, a sample of 1987-89 private insurance claims data (for individuals under age 65) was purchased from MEDSTAT Systems, Inc. (Ann Arbor, MI).3

[3] The data presented in this section are derived from Earl P. Steinberg, MD, MPP, et al., "The Content and Cost of an Episode of Cataract Surgery," manuscript submitted for publication.

In summary, this analysis suggests that Medicare expended approximately $3.4 billion in connection with cataract surgery in 1991. Of this, only $64 million (2 percent) is estimated to have been spent on miscellaneous ophthalmic diagnostic tests and perioperative medical services. The primary determinants of Medicare's cost of cataract surgery are thus the overall frequency with which cataract surgery and YAG laser capsulotomy are performed and the amounts paid for these core components of an episode of cataract surgery.

## Methodology

### Development of Methods and Questions

To prepare for the development of the guidelines by the panel, a meeting of the Ad Hoc Literature Review Group was held in Washington on July 19, 1990. The purpose was to develop a list of literature search questions to be answered by the literature review. It was decided that the questions would be oriented toward aspects of the care of patients with functional impairment due to cataract as they relate to outcome. The questions were divided into 13 categories. At the same time, criteria for including and excluding articles in the literature review were also developed.

A two-pronged approach to the literature search was devised in which both content and methodologic quality would be evaluated. The Ad Hoc Literature Review Group unanimously agreed that content relevance was of prime importance in establishing the literature to be reviewed for this panel. To achieve this goal, teams of content experts would first review and select the publications based on content relevance. Methodologists would then review the selected publications and come to consensus regarding quality and conclusions, using criteria established to ensure appropriate rigor. A content review team leader and a methodologist for each category would be appointed.

This overall approach, the literature search questions, and the inclusion/exclusion criteria developed by the Ad Hoc Literature Review Group were approved by the guideline panel at its first meeting in August 1990. The content review team leaders were then selected by Denis O'Day, MD, Panel Chair, on the basis of known expertise in the area under consideration. Subsequently, team leaders in collaboration with Dr. O'Day appointed literature review team members. A similar approach was used to select methodologists for the project.

The members of the Ad Hoc Literature Review Group decided to use the data bases of the National Library of Medicine as the foundation. Because of the limitations of timeliness and breadth inherent in such data bases, less formal methods of literature search were also used. These included reviewing research and professional meeting abstracts, writing to journal editors of impending and relevant articles, reviewing government studies, and surveying interest groups for relevant information.

As a result of the informal literature search process, two articles considered worthy of review were brought to the attention of the Ad Hoc Literature Review Group during the open forum. These articles dealt with cataract practice patterns and were sponsored, cited, and widely distributed by special interest groups advocating certain types of practice patterns. These articles were not published in a peer-review journal and were not annotated by the National Library of Medicine.

In light of the unique circumstances surrounding these publications and for the benefit of the panel, it was decided to review these separately. These full reviews are included in Appendix A in the Guideline Report. They are the reviews by William Stason, MD, and Steven Woolf, MD, MPH, of the Society of Geriatric Ophthalmology Special Report on Cataract Care and the review by Dr. Woolfof the Battelle Study, "Outcomes of Cataract Surgery With Co-Managed Postoperative Care" (Revicki, Brown, and Adler, 1990).

#### Eligibility Criteria.

The literature review for developing the guidelines was based primarily on published articles identified by searchers of electronic data bases. They adhered to the following eligibility criteria:

- Articles were included only if the report focused on more than 10 individuals.
- Articles describing triple procedures for corneal disease or glaucoma were excluded.
- Research reported in articles must have focused on senile and presenile cataracts and cataracts related to diabetes. Congenital cataracts were excluded from the review, and traumatic cataracts were also excluded.
- Animal studies were excluded.
- Post mortem studies were excluded unless other patient data were included.
- Unpublished literature was acceptable.

The literature review was limited to articles published in English from January 1, 1975, through December 31, 1990. (For the review of surgical techniques and complications, the search was extended through April 1991.) However, peer reviewers brought to the panel's attention some relevant literature published after the cutoff date. If it appeared that the more recent items might alter the guideline, they were included in the review. Additional information on these inclusions is given in the Guideline Report.

#### Reference Sources.

Trained searchers developed and conducted searches of electronic data bases at the National Library of Medicine. The specific search strategies used are included in Appendix A in the Guideline Report. The combined data base sources used for searching were:

- MEDLINE (1975 to January 26, 1991).
- Cumulative Index to Nursing and Allied Health Abstracts file (CINAHL) (1983 to August 1, 1990).
- Psychological Abstracts (1975 to September 1, 1990).
- Catline (books) (1975 to August 1, 1990).
- Health (1975 to August 1, 1990).
- Dissertation Abstracts (1960 to September 1, 1990).
- Science Citation Index (1987 to March 1991) (SCISearch).

Other nonelectronic sources of references were also utilized. These included:

- Ad hoc notification by guideline panel or team members regarding specific reports that should be included.
- References obtained from a machine-readable reprint file from the RAND Corporation project on cataracts.
- An article by Kerry B. Kemp and Barbara Boardman in Vision Research: A National Plan, 1983-1987.
- Several articles from Health Devices, a technology assessment journal that conducts engineering assessments of medical devices on phacoemulsification.
- An article from the Battelle Human Affairs Research Center entitled "Outcomes of Cataract Surgery With Co-Managed Postoperative Care" (Revicki, Brown, and Adler, 1990).

In addition, peer reviewers submitted a few items not previously identified through the systematic literature review. If these items met the inclusion criteria and provided additional information, they were included. (See Appendix Q of the Guideline Report for more information on these inclusions.)

#### Definitions Used in Constructing Literature Search Questions.

The following definitions were used in constructing literature search questions to be answered by the literature review:

Timing: Timing of surgery refers to the stage of disease, as specified by degree of functional impairment.

Volume: Number of surgical procedures performed by surgeon in specific time period.

Positive Outcome: Degree to which the presurgical functional impairment is relieved by the surgery, as defined by the following types of benefits perceived by the patient, members of the patient's family, or the ophthalmologist:

- Increased ability to read or do close work.
- Increased ability to perform minimal everyday activities.
- Increased opportunity to continue or resume function or occupation (working, playing, driving) due to improvement in vision.
- Restoration of functional ability to precataract level.
- Increased mobility.
- Increased independence.
- Better uncorrected vision.
- Improved color vision.
- Reduced glare disability.
- Improved depth perception.
- Increased ability to retain a quiet eye with no treatment-induced disorders.
- Increased patient satisfaction with the results of surgery.
- Improved sense of mental well-being.
- Improved self-esteem.
- Relief from fear of going blind.
- Increased ability to avoid injury.
- Increased interpersonal contact.
- Increased opportunity for medical observation of the internal eye for incipient or impending diseases.

Negative Outcome: The failure to relieve (improve) preoperative functional impairment as perceived by the patient, the patient's family, or the ophthalmologist. In addition, negative outcome refers to the development of complications that either impair the patient's visual function or consume resources. Examples of negative outcomes include:

- Death.
- Loss of eye.
- Loss of vision.
- Risk to the other eye.
- Presence of preventable and significant side effects and complications.
- Infection.
- Retinal detachment.
- Imbalance in the power of the lenses.
- Glare problems.
- Corneal problems.
- Hyphema.
- Increased intraocular pressure (IOP).
- Cystoid macular edema.
- Expulsive hemorrhage.
- Glaucoma.
- Ptosis.
- Dislocated IOL.
- Increased risk of pupil dilation.
- Systemic morbidity as a result of the operation.
- Dissatisfied patient.
- Quality of life worsened.
- Painful eye.
- Disorientation.
- Black patch psychosis.
- Self-harm through overestimating abilities.
- Fractured hip.
- Increased need for ocular medication.
- Adverse systemic effects of ocular drugs.
- Increased ultraviolet exposure.
- Decreased mobility.
- Need for further surgery.
- Loss of job.
- Failure to improve.

#### Specific Search Questions.

The search questions constructed by the Ad Hoc Literature Review Group are discussed in the relevant chapters of this report. The categories of search questions are as follows:

- Category 1: Natural History
- Category 2: Referral Pathways and Access to Care
- Category 3: Setting and Providers of Care
- Category 4:Tests of Visual Function: Contrast Sensitivity Testing, Glare Testing, and Potential Vision Testing
- Category 5: Specular Photographic Microscopy
- Category 6: Indications for Cataract Surgery
- Category 7: Preoperative Medical Evaluation
- Category 8: Anesthesia
- Category 9: Surgical Techniques and Complications
- Category 10: Second Eye Surgery
- Category 11: Postoperative Care
- Category 12: Rehabilitation
- Category 13: Posterior Capsular Opacification -- YAG Capsulotomy
- Category 14: Selection of IOL
- Category 15: Nonsurgical Management of Cataract
- Categories 14 and 15 were not researched.

### Selection of Potentially Relevant Articles

Printouts of the citations were sent to expert literature reviewers (abstract reviewers) to review and from which to select articles that appeared to be potentially relevant. In this first stage, the purpose of the selection process was to be "sensitive" as opposed to "specific." That is, the goal was to avoid overlooking any potentially relevant articles rather than to identify only articles that were definitely relevant to the question at hand.

Complete copies of the selected articles were retrieved from periodicals and reviewed by team leaders to determine whether articles satisfied the eligibility criteria. The same articles were also reviewed by methodologic evaluators for each team. The methodologist and team leader then communicated with one another to agree on a common set of articles deemed relevant for evaluation.

### Development of Literature Evaluation Forms

The process of developing literature evaluation forms was concurrent with the process of identifying relevant articles. Two forms (a methodologic form and a content form) were used in evaluating an article. The methodologic form was developed by the methodologist for the team, and it addressed the following issues:

- Type of study design employed.
- Description of the patient population.
- Inclusion/exclusion criteria.
- Bias in patient selection.
- Sample size.
- Use of a comparison group.
- Potential bias in selection of patients or controls.
- Standardization of exposure or intervention.
- Standardization of definition and measurement of outcome.
- Use of masking of randomization.
- Duration of followup specified.
- Handling of attrition.
- Consideration of nonindependence of eyes for a single patient.
- Issues related to external validity of the study.

The content form typically was designed to address the specific search questions decided on by the Ad Hoc Literature Review Group in July 1990 and approved by guideline panel members in August 1990. These forms were generally developed by team leaders, with assistance from other Ad Hoc Literature Review Group members as needed.

### Assessment of Content and Methodology

Once the final set of articles was selected for abstraction by content and methodology reviewers, copies of selected articles were mailed to members of each team for review and evaluation.

All articles mailed to the content reviewers were masked, so that the authors, their institutions, and the journal and year of publication were not visible. Articles were assigned to methods and content teams, with a common set of articles assigned to at least two members of those teams to allow assessment of interrater reliability.

Completed forms for the content reviews were returned to the team leader for summarization and analysis, and completed methods forms were returned to the methodologist for the same.

Interrater reliability for both the content and methods review was assessed by comparing duplicate abstractions by separate readers for the same article. For sections where only a few articles were evaluated, all articles were read and abstracted in duplicate and compared for reliability. When large numbers of articles were assessed, a sample of all articles was read and abstracted in duplicate and compared. Specific methods are described in the relevant chapters.

For the most part, no formal statistical analyses were done; rather the evidence was summarized in tabular form. The major reason for this was that study designs tended to vary substantially in clinically and methodologically significant ways. For example, patient eligibility criteria, outcome measures and definitions, and duration of followup varied substantially, precluding meaningful "pooling" of results.

### Writeup of Literature Reviews

The panel was provided with drafts of the literature review results as they were completed. In some instances, the panel requested additional information that the members thought should be sought from the available literature. For example, in the case of potential vision, after the literature was initially reviewed and summarized in draft form, the panel requested a second review of the literature in order to identify articles containing data relevant to the effect of macular disease on the sensitivity and specificity of potential vision testing.

The reports for each of the sections of the Guideline Report were constructed in the same way. The Results section listed the questions initially identified by the Ad Hoc Literature Review Group and described the literature relevant to each question that met the inclusion criteria. The results of the literature review were also summarized in evidence tables.

In the chapters, text labeled "Discussion" centered on, first, the methodology of the studies included in the review and, second, their results. Sections labeled "Conclusions" were based primarily on the literature review. Only rarely did the panel present conclusions that were not based on the literature. When they did, they were careful to note where conclusions were based on the literature and where they expressed consensus opinion.

### Consensus Process

In several cases, notably preoperative medical evaluation, there was very little available literature specifically appropriate to cataract surgery. In this case, guidelines that are not specific to cataract surgery were described, referencing the general medical literature where possible. Another example of a situation with little or no relevant literature was the chapter on Referral Pathways. When the panel needed to reach a consensus on an issue because of lack of data in the published literature, the mechanism was as follows: the person responsible for the chapter for which little or no data were available would write the chapter and conclusions based either on related literature, prior guidelines, or opinion. As with all chapters of the Guideline Report, the draft was distributed by mail to panel members for feedback. Using input from panel members, the responsible person would revise the draft several times prior to the next scheduled panel meeting. At the panel meeting, there would be considerable discussion regarding all conclusions, but in particular about conclusions for which a consensus had to be reached because there were no available data. At each panel meeting, drafts would be rereviewed and discussed again at length. The consensus process always involved panel members, and they were the only ones allowed to vote. No final decisions were made on chapters and their conclusions other than at panel meetings.