# Acronyms

AHCPR: Agency for Health Care Policy and Research

ANA: American Nurses Association

ARN: Association of Rehabilitation Nurses

CURN: Conduct and Utilization of Research in Nursing

DHHS: U.S. Department of Health and Human Services

IAET: International Association for Enterostomal Therapy

NLM: National Library of Medicine

NPUAP: National Pressure Ulcer Advisory Panel

OBRA: Omnibus Budget Reconciliation Act

PHS: Public Health Service