# Glossary

Air Fluidized Bed:: Class of support devices that uses a high flow rate of air to fluidize a fine particulate material such as sand to produce a support medium that has characteristics very similar to a liquid.

Air Flotation Bed:: Generic descriptor for low air loss beds and air fluidized beds.

Completely Immobile:: Inability to move or reposition without assistance.

Debride:: Removal of foreign material and dead or damaged tissue.

Dry Lubricant:: Solid material usually in the form of a very thin film or powder: corn starch, copolymer, or teflon.

Dynamic Support Surface:: Pressure-reducing device that is designed to cyclically change its support characteristics; examples include alternating air mattresses and mechanical seats that change shape and redistribute pressure.

Eschar:: Thick, leathery, necrotic, devitalized tissue.

Interface Pressure:: Force per unit area that acts perpendicularly between the body and the support surface. This parameter is affected by the stiffness of the support surface, the composition of the body tissue, and the geometry of the body being supported.

Low Air Loss Bed:: Class of support devices that is characterized by a system of air-filled pillows that act much like a static air-filled device. The bed is composed of a large number of pillows in which the inflation pressure can be adjusted so that the support characteristics of the bed are matched to those of the body being supported.

Lubricant:: Substance used to lower the coefficient of friction between two other materials.

Mechanical Loading:: Mechanical forces that may contribute to development of pressure ulcers (pressure, friction, and shear).

Moisture:: Skin moisture, primary sources of which include perspiration, urine, feces, drainage from wounds, or fistulas (Braden and Bergstrom, 1987).

Necrosis:: Death of tissue.

Nonblanchable Erythema:: Redness of skin surface that persists when pressure is applied.

Pressure Reduction:: Reduction of interface pressure, not necessarily below capillary-closing pressure.

Pressure Relief:: Reduction of interface pressure below capillary-closing pressure (adapted from Maklebust and Sieggreen, 1991).

Pressure Ulcer:: Any lesion caused by unrelieved pressure resulting in damage of underlying tissue. Pressure ulcers are usually over bony prominences and are graded or staged to classify the degree of tissue damage observed. The staging of pressure ulcers recommended for use by this panel is consistent with the recommendations of the National Pressure Ulcer Advisory Panel (NPUAP, 1989) as derived from previous staging systems proposed by Shea (1975) and the International Association for Enterostomal Therapy (IAET, 1988). The staging is as follows: Stage I: Nonblanchable erythema of intact skin; the heralding lesion of skin ulceration. Note: Reactive hyperemia can normally be expected to be present for one-half to three-fourths as long as the pressure occluded blood flow to the area (Lewis and Grant, 1925). This should not be confused with a Stage I pressure ulcer. Stage II: Partial thickness skin loss involving epidermis and/or dermis. The ulcer is superficial and presents clinically as an abrasion, blister, or shallow crater. Stage III: Full thickness skin loss involving damage or necrosis of subcutaneous tissue that may extend down to, but not through, underlying fascia. The ulcer presents clinically as a deep crater with or without undermining of adjacent tissue. Stage IV: Full thickness skin loss with extensive destruction, tissue necrosis, or damage to muscle, bone, or supporting structures (for example, tendon or joint capsule). Note: Undermining and sinus tracts may also be associated with Stage IV pressure ulcers. Staging definitions recognize the following limitations: Assessment of Stage I pressure ulcers may be difficult in patients with darkly pigmented skin.When eschar is present, accurate staging of the pressure ulcer is not possible until the eschar has sloughed or the wound has been debrided.

Reactive Hyperemia:: Reddening of the skin caused by blood rushing back into ischemic tissue (Maklebust and Sieggreen, 1991).

Repositioning:: Any change in body position that removes pressure from tissue overlying bony prominences. Periodic repositioning of chair-bound and bed-fast individuals is one of the most basic and frequently used methods of pressure reduction. The overall goal of repositioning is to allow tissue reperfusion prior to ischemic tissue changes. Repositioning implies a sustained relief of pressure, not just a temporary shift. Recommendations for frequency of repositioning and specific repositioning techniques can be found in the body of this document. Recommendations should be individualized according to the level of risk and specific goals of the patient.

Sebum:: Secretion of the sebaceous glands.

Shear:: Force per unit magnitude of the area acting parallel to the surface of the body. This parameter is affected by the pressure, the coefficient of friction between the materials contacting each other, and how much the body interlocks with the support surface.

Static Support Surface:: Pressure-reducing device designed to provide support characteristics that do not cycle in time. Examples include foam overlays and water mattresses.

Stratum Corneum:: Outermost layer of the epidermis.

Tissue Tolerance:: The ability of both the skin and its supporting structures to endure the effects of pressure without adverse sequelae (Braden and Bergstrom, 1987).

Topical Agents:: For the purposes of this document, topical agents are a broad category of creams, lotions, and skin preparations applied externally. Some topical agents may serve as moisture barriers, protecting the skin from external sources of moisture.

Trochanter:: Bony prominence on the upper part of the femur.