# Executive Summary

## Introduction

The incidence and prevalence of pressure ulcers are high enough to warrant concern among the hospitalized and nursing home populations as well as among persons receiving care at home. In hospitals, the incidence of pressure ulcers ranged from 2.7 percent (Gerson, 1975) to 29.5 percent (Clarke, and Kadhom, 1988); one extensive study of acute care facilities found a prevalence of 9.2 percent (Meehan, 1990). Several subpopulations may be at higher risk, including quadriplegic patients (60 percent prevalence) (Richardson, and Meyer, 1981), elderly patients admitted for femoral fracture (66 percent incidence) (Versluysen, 1986), and critical care patients (33 percent incidence) (Bergstrom, Demuth, Braden, 1987).

Among persons in skilled care and nursing home-type facilities, prevalence of pressure ulcers was found to be 23 percent (Langemo, Olson, Hunter, et al., 1989; Young, 1989). The prevalence among persons cared for in home settings with supervision or assistance of professionals is not fully understood because there is little research on the subject.

The purpose of this guideline is to help identify adults at risk of pressure ulcers, to define early interventions for prevention, and to manage Stage I pressure ulcers.

This guideline is intended for adults at risk for development of pressure ulcers. The guideline is not intended as a basis for care of infants and children, nor do recommendations apply to individuals with existing Stage II or greater pressure ulcers or to individuals who are fully mobile. A pressure ulcer is any lesion caused by unrelieved pressure resulting in damage of underlying tissue. Pressure ulcers usually occur over bony prominences and are graded or staged to classify the degree of tissue damage observed.

Stage I pressure ulcers are defined as nonblanchable erythema of intact skin -- the heralding lesion of skin ulceration (reactive hyperemia should not be confused with Stage I pressure ulcers). Stage II is defined as partial thickness skin loss involving epidermis and/or dermis; Stage III as full thickness skin loss involving damage or necrosis of subcutaneous tissue that may extend down to, but not through, underlying fascia; and Stage IV as full thickness skin loss with extensive destruction, tissue necrosis or damage to muscle, bone, or supporting structures.

The following limitations in assessment are recognized: (1) identification of Stage I pressure ulcers may be difficult in patients with darkly pigmented skin and (2) when eschar is present, accurate staging of the pressure ulcer is not possible until the eschar has sloughed or the wound has been debrided.

To develop the guideline, AHCPR convened an interdisciplinary non-Federal panel of physicians, nurses, an occupational therapist, a basic scientist, a biomedical engineer, and a health care consumer. In developing the scientific base to support guideline recommendations, the panel conducted an extensive literature review of pressure ulcers in adults. It also heard public testimony at an open forum and examined information from consultants. A revised draft of the guideline received peer review and pilot review.

Interventions the panel considered included early detection maneuvers, such as risk factor identification, and laboratory tests for screening of nutritional status. Treatments evaluated included those broadly conceptualized as pressure reduction or relief and strategies to maintain tissue tolerance. The panel considered a broad range of interventions but did not select interventions that were not supported by two or more clinical studies and not recommended in clinical practice.

The guideline recommendations are intended for clinicians who examine and treat persons at risk of developing pressure ulcers. These clinicians include family physicians, internists, geriatricians, occupational and physical therapists, nurses, nurse practitioners, and dietitians working in a variety of health care settings such as acute care, rehabilitation, and home- and community-based settings. The recommendations also should be useful to patients and family members, health care administrators, policy analysts, and others.

This guideline's overall goal is prevention of pressure ulcers, which is less costly than treatment, both in terms of human suffering and financial costs. Risk predictor tools improve the ability of practitioners to predict who will or will not develop pressure ulcers. Knowledge of risk status permits the practitioner to target certain individuals for preventive measures. Although preventive measures may be applied with little or no risk to all individuals, some measures are costly; targeting prevention only to persons at risk for developing pressure ulcers will reduce the costs of prevention.

Most pressure ulcers can be prevented, and those Stage I pressure ulcers that do appear need not worsen under most circumstances. However, even the most vigilant nursing care may not prevent the development and worsening of ulcers in some very high-risk individuals. In those cases, intensive therapy must be aimed at reducing risk factors (such as improving nutritional status), at preventive measures (such as frequent turning, and mattress overlays), and at treatment.

Guideline recommendations should be viewed in light of the overall goals of patient care. Prevention of pressure ulcers is imperative when the overall goal is to cure an illness, to rehabilitate the individual, or to help the individual live optimally with a chronic illness. However, when an individual is in the latter stages of a terminal illness and is suffering intractable pain, the primary goal of therapy may be to promote comfort and decrease pain. In this case, frequent repositioning, nutritional support, and other strategies to prevent pressure ulcers may not be consistent with the goal of promoting comfort.

## Risk Assessment Tools and Risk Factors

Goal: Identify at-risk individuals needing prevention and the specific factors placing them at risk.

Bed- and chair-bound individuals or those with impaired ability to reposition should be assessed for additional factors that increase the risk of developing pressure ulcers. These factors include immobility, incontinence, nutritional factors such as inadequate dietary intake and impaired nutritional status, and altered level of consciousness. Individuals should be assessed on admission to acute care and rehabilitation hospitals, nursing homes, home care programs, and other health care facilities. A systematic risk assessment can be accomplished by using a validated risk assessment tool such as the Braden Scale or the Norton Scale. Pressure ulcer risk should be reassessed at periodic intervals.

## Skin Care and Early Treatment

Goal: Maintain and improve tissue tolerance to pressure in order to prevent injury.

All individuals at risk should have a systematic skin inspection at least once a day, with particular attention to the bony prominences; results should be documented. Skin should be cleansed at time of soiling and at routine intervals. The frequency of skin cleansing should be individualized according to need and/or patient preference. Avoid hot water, and use a mild cleansing agent that minimizes irritation and dryness of the skin. During the cleansing process, care should be taken to minimize the force and friction applied to the skin. Preliminary research suggests some association between dry, flaky, or scaling skin and an increased incidence of pressure ulcers (Guralnik, Harris, White, et al., 1988). Environmental factors leading to skin drying, such as low humidity (less than 40 percent) and exposure to cold, should be minimized. Dry skin should be treated with moisturizers.

Avoid massage over bony prominences. Although such massage has been used for decades, the scientific evidence for using massage to stimulate blood flow and avert pressure ulcer formation is not well established, whereas there is preliminary evidence suggesting it may lead to deep tissue trauma.

Minimize skin exposure to moisture due to incontinence, perspiration, or wound drainage. When these sources of moisture cannot be controlled, underpads or briefs made of materials that absorb moisture and present a quick-drying surface to the skin can be used. Topical agents that act as barriers to moisture may also be used.

Skin injury due to friction and shear forces should be minimized through proper positioning, transferring, and turning techniques. In addition, friction injuries may be reduced by the use of lubricants (such as corn starch, and creams), protective films (such as transparent film dressings, and skin sealants), protective dressings (such as hydrocolloids), and protective padding.

Adequate dietary intake of protein and calories should be maintained. When apparently well-nourished individuals develop an inadequate dietary intake of protein or calories, caregivers should first attempt to discover and correct the factors compromising intake and offer support with eating. Other nutritional supplements or support may be needed. If dietary intake remains inadequate and if consistent with overall goals of therapy, more aggressive nutritional intervention such as enteral or parenteral feedings should be considered. For nutritionally compromised persons, a plan of nutritional support and/or supplementation should be implemented to meet individual needs and the overall goals of therapy.

Maintain current activity level, mobility, and range of motion if appropriate. If the potential for improving mobility and activity status exists and is consistent with overall goals of therapy, rehabilitation efforts should be instituted.

Interventions should be monitored and documented. Specific details are needed on who should provide the care, how often, and the supplies and equipment needed. How the care is to be undertaken should be individualized, written, and readily available. Furthermore, results of the interventions and the care being rendered, and adjustment in the interventions, as indicated by the outcomes should be documented. To ensure continuity, documentation of the plan of care must be clear, concise, and accessible to every caregiver.

## Mechanical Loading and Support Surfaces

Goal: Protect against adverse effects of external mechanical forces: pressure, friction, and shear.

Individuals in bed assessed to be at risk for developing pressure ulcers should be repositioned at least every 2 hours if consistent with overall patient goals. A written schedule for systematically turning and repositioning the individual should be used. Positioning devices such as pillows or foam wedges should be used to keep bony prominences (for example, knees or ankles) from direct contact with one another, again according to a written plan.

Individuals who are completely immobile should have a care plan that includes the use of devices that totally relieve pressure on the heels, most often by raising them off the bed. Donut-type devices should not be used. Ring cushions are known to cause venous congestion and edema. Although few studies have documented their deleterious effects, one study of at-risk patients found that ring cushions (donuts) are more likely to cause than to prevent pressure ulcers (Crewe, 1987). Other recommendations include not positioning the individual directly on the trochanter when the side-lying position is used and maintaining the head of the bed at the lowest degree of elevation consistent with medical conditions and other restrictions. The amount of time the head of the bed is elevated should be limited. Anyone assessed to be at risk for developing pressure ulcers should be placed on a pressure-reducing device when lying in bed -- such as foam, static air, alternating air, gel, or water mattresses. Lifting devices such as a trapeze or bed linen should be used to move, rather than drag, individuals who cannot assist during transfers and position changes.

Uninterrupted sitting by at-risk individuals in chairs or wheelchairs should be avoided. If consistent with overall patient management goals, the individual should be repositioned, shifting the points under pressure, at least every hour or be put back to bed. Individuals who are able to move should be taught to shift weight every 15 minutes. For individuals who sit in wheelchairs or on other sitting surfaces, the use of a pressure-reducing device such as those made of foam, gel, air, or a combination is indicated -- but not donut-type devices. Positioning in the chair should include consideration of postural alignment, distribution of weight, balance and stability, and pressure relief. A written plan for the use of positioning devices and schedules may be helpful for chair-bound individuals.

## Education

Goal: Reduce the incidence of pressure ulcers through educational programs.

The programs should be structured, organized, and comprehensive and directed at all levels of health care providers, patients, and family/ caregivers. An educational program for prevention of pressure ulcers should include information on etiology and risk factors, risk assessment tools and their application, skin assessment, selection and/or use of support surfaces, development and implementation of an individualized program of skin care, demonstration of positioning to decrease risk of tissue breakdown, and instruction on accurate documentation of pertinent data.

The educational program should identify those responsible for pressure ulcer prevention, describe each person's role, be appropriate to the audience in terms of level of information presented and expected participation, and be updated regularly to incorporate new and existing techniques or technologies. More continuity of care is reported when team approaches are used and each person on the team has specific, identified responsibilities. Principles of adult learning should be used to develop, implement, and evaluate educational programs; established programs must have built-in mechanisms to evaluate their effectiveness.