# Acknowledgments

Many organizations and individuals made significant contributions during the development of this guideline, and their assistance only can be briefly noted. Peer reviewers, individuals at institutions that provided pilot review, and consultants are acknowledged individually in the Contributors section.

All persons, organizations, and agencies with an interest in the pressure ulcer guideline were invited to participate at a public meeting held in Washington, DC, on December 6, 1990. The panel gratefully acknowledges the valuable input received.

The guideline certainly benefitted from review at the National Pressure Ulcer Advisory Panel (NPUAP) conference, March 6-8, 1991. Experts analyzed the guideline for its legal, ethical, fiscal, administrative, clinical medicine and nursing, educational, and research impact. Small group sessions analyzed how the guideline would affect acute care, long-term care, and home care. NPUAP, the International Association for Enterostomal Therapy (IAET), and the Association of Rehabilitation Nurses sponsored the conference and suspended plans in order to accommodate the need of the panel for multidisciplinary input.

Contributions of product manufacturers to the guideline development process are also gratefully acknowledged by the panel. Many companies responded to requests for published and unpublished information describing results of product research.

Margaret Coopey, MGA, RN; Marietta Anthony, PhD; Sue Hopkinson, MPP, RN; and Kathleen Hastings, RN, JD, MPH; were health policy analysts for the guideline at different times for the Office of the Forum for Quality and Effectiveness in Health Care, AHCPR. William N. LeVee, Center for Research Dissemination and Liaison, AHCPR, provided editorial review and production management.

Finally, the panel thanks the support staff members for their tireless efforts: Janet Cuddigan, MSN, RN, project coordinator and research analyst; Brenda Bergman, MS, RNC, research analyst; and Elizabeth Gavin, panel secretary.