# Panel Members

- Nancy Bergstrom, PhD, RN, FAAN, Chair
- Professor of Nursing
- College of Nursing
- University of Nebraska Medical Center
- Omaha, Nebraska
- Specialty: Nurse Researcher and Educator

- Richard M. Allman, MD
- Associate Professor of Medicine
- Director of the Division of Gerontology and Geriatric Medicine
- University of Alabama at Birmingham
- Birmingham, Alabama
- Specialty: Geriatric Physician

- Carolyn E. Carlson, PhD, RN
- Professor of Nursing
- Cedarville College
- Associate Director of Nursing and Allied Health for Research and Evaluation,
- Divisions of Nursing and Allied Health, and Department of Research
- Rehabilitation Institute of Chicago
- Chicago, Illinois
- Specialty: Nurse Educator and Researcher

- William Eaglstein, MD
- Professor and Chairman Department of Dermatology and Cutaneous Surgery
- University of Miami School of Medicine
- Miami, Florida
- Specialty: Dermatologist

- Rita A. Frantz, PhD, RN, FAAN
- Associate Professor, College of Nursing
- University of Iowa
- Clinical Associate in Nursing,
- Iowa Veteran's Home
- Iowa City, Iowa
- Specialty: Nurse Educator and Researcher

- Susan L. Garber, MA, OTR
- Assistant Director for Research
- Department of Occupational Therapy
- The Institute for Rehabilitation and Research
- Assistant Professor
- Department of Physical Medicine and Rehabilitation
- Baylor College of Medicine
- Houston, Texas
- Specialty: Occupational Therapist

- Davina Gosnell, PhD, RN, FAAN
- Professor and Dean
- Kent State University School of Nursing
- Kent, Ohio
- Specialty: Nurse Educator and Researcher

- Bettie S. Jackson, EdD, MBA, FAAN
- Director of Professional Nursing Services
- Moses Division, Montefiore Medical Center
- Associate Research Scientist
- Columbia University School of Nursing
- Bronx, New York
- Specialty: Enterostomal Therapy Nurse

- Mildred G. Kemp, PhD, RN, CETN, FAAN
- Associate Professor
- Rush University College of Nursing
- Practitioner/Teacher
- Department of Operating Room and Surgical Nursing
- Rush-Presbyterian-St. Luke's Medical Center
- Chicago, Illinois
- Specialty: Enterostomal Therapy Nurse

- Thomas A. Krouskop, PhD
- Professor, Department of Physical Medicine and Rehabilitation
- Baylor College of Medicine
- The Institute for Rehabilitation and Research
- Houston, Texas
- Specialty: Bioengineer

- Elena M. Marvel, MSN, MA, RN
- State Coordinator
- Health Advocacy Services Program in New Jersey
- American Association of Retired Persons
- Short Hills, New Jersey
- Specialty: Consumer Representative

- George T. Rodeheaver, PhD
- Professor and Director of Plastic Surgery Research
- University of Virginia Health Sciences Center
- Charlottesville, Virginia
- Specialty: Researcher, Wound Management

- George C. Xakellis, MD
- Associate Professor of Family Medicine
- University of Iowa College of Medicine
- Iowa City, Iowa
- Specialty: Family Practice Physician