# Foreword

The occurrence of pressure ulcers in patients in different settings is high enough to warrant concern, especially in certain high-risk groups. Prevalence in skilled care and nursing home facilities is approximately 23 percent. In the most extensive study of acute care facilities, there was a prevalence of 9.2 percent. Special high-risk populations include quadriplegic patients (60 percent prevalence in one study) and elderly patients admitted for femoral fracture (66 percent incidence).

Prevention of pressure ulcers in adults at risk is the overall goal of this guideline. Most can be prevented, and those Stage I pressure ulcers (nonblanchable erythema of intact skin) that do form need not worsen. Recommendations target four goals: (1) identifying at-risk individuals who need preventive intervention and the specific factors placing them at risk; (2) maintaining and improving tissue tolerance to pressure in order to prevent injury; (3) protecting against the adverse effects of external mechanical forces (pressure, friction, and shear); and (4) reducing the incidence of pressure ulcers through educational programs.

This guideline is intended for clinicians who examine and treat persons at risk of developing pressure ulcers. AHCPR commissioned an external panel of multidisciplinary experts in the field to develop the guideline. Guideline development included a broad range of input from professional and consumer organizations and individuals.

To build a scientific basis for the guideline, the panel reviewed comprehensive literature searches and then evaluated approximately 800 manuscripts. The panel also solicited input from a broad array of organizations and individuals. Testimony was invited at a public meeting. A draft of the guideline was analyzed by experts at a conference sponsored by the National Pressure Ulcer Advisory Panel, the International Association for Enterostomal Therapy, and the Association of Rehabilitation Nurses. In addition, the guideline received peer review (of the literature review and the conclusions reached) and pilot review by health care agencies to evaluate the guideline both conceptually and informally on a small number of patients (some sites also provided a more formal evaluation).

This is the first edition of Pressure Ulcers in Adults: Prediction and Prevention; it will be revised and updated as needed. Future editions will reflect new research findings and experience with the incorporation of emerging technologies and innovative approaches. The panel welcomes comments and suggestions on the guideline for use in the next edition. Please send written comments to Director, Office of the Forum for Quality and Effectiveness in Health Care, AHCPR, Executive Office Center, Suite 401, 2101 East Jefferson Street, Rockville, MD 20852.

Panel for the Prediction and Prevention of Pressure Ulcers in Adults