# Research Agenda

A comprehensive review of the literature related to the prediction and prevention of pressure ulcers in adults was completed in 1991 by the guideline panel. Recommendations were made in this guideline on the basis of the best available information from that review, but when it was concluded, the panel found that much clearly remains to be studied.

Recommendations for future research focus on several major needs. Specifically, the panel found the following needs:

- Outcome-focused research.
- Research on the relative efficacy of specific interventions and products.
- Basic research related to defining the outcome of treatment.
- Further refinement of risk assessment methods.
- Risk-based, multi-intervention, multisite trials.

Additional issues requiring investigation are related to:

- The relative cost of prevention versus the cost of treatment.
- Ethical decisionmaking related to patient rights and goals of treatment.
- The effect of the guideline on public policy and national outcomes.

Specific methodological problems need to be addressed in future work to increase the quality and trustworthiness of the data. Studies of product efficacy and treatment effectiveness must be conducted on at-risk patients in clinical situations rather than on normal subjects or animals in laboratory settings. These studies must compare equivalent products and use appropriate control groups. The entire care regimen of the control and experimental groups should be clearly defined and equivalent.

Methods for dissemination of knowledge to members of the multidisciplinary team, patients, and their families need to be tested. Further, health care delivery issues that alter implementation of the guideline and protocols need to be understood. These issues include staffing and acuity levels, resources (cost, space, and time), and caregiver sophistication.