# Algorithm

The algorithm that follows was developed as a visual display of the conceptual organization, procedural flow, decision points, and preferred management path discussed in the guideline. It begins at the point of admission to an acute care hospital, rehabilitation hospital, nursing home, home care program, or other health care facility or program. Numbers in the algorithm refer to the annotations that follow.

Pressure Ulcer Prediction and Prevention Algorithm

## Activity or Mobility Deficit

### 1. Activity or Mobility Deficit:

Bed- or chair-bound individuals or those whose ability to reposition is impaired should be considered at risk for pressure ulcers. Identification of additional risk factors (immobility, moisture/incontinence, and nutritional deficit) should be undertaken to direct specific preventive treatment regimes.

### 2. Educational Program:

Educational programs for the prevention of pressure ulcers should be structured, organized, and comprehensive and directed at all levels of health care providers, patients, and family or caregivers. Refer to Educational Guideline 1, 2, 3, 4(pages 27-30).

### 3. Reassessment:

Active, mobile individuals should be periodically reassessed for changes in activity and mobility status. The frequency of reassessment depends on patient status and institutional policy.

### 4. Risk Assessment Tools:

Clinicians are encouraged to select and use a method of risk assessment that ensures systematic evaluation of individual risk factors. Many risk assessment tools exist, but only the Norton Scale and Braden Scale have been tested extensively.

Risk assessment tools include the following risk factors: mobility/activity impairment, moisture/incontinence, and impaired nutrition. Altered level of consciousness (or altered sensory perception) is also identified as a risk factor in most assessment tools. Identification of individual risk factors (boxes 5-7) is helpful in directing care.

### 5. Mobility/Activity Deficit:

If there is a deficit, see boxes 8 and 9.

#### Mechanical Loading and Support Surfaces

Mechanical Loading and Support Surface Guideline (pages 22-27)

For bed-bound individuals:

- Reposition at least every 2 hours.
- Use pillows or foam wedges to keep bony prominences from direct contact.
- Use devices that totally relieve pressure on the heels.
- Avoid positioning directly on the trochanter.
- Elevate the head of the bed as little and for as short a time as possible.
- Use lifting devices to move rather than drag individuals during transfers and position changes.
- Place at-risk individuals on a pressure-reducing mattress. Do not use donut-type devices.

For chair-bound individuals:

- Reposition at least every hour.
- Have patient shift weight every 15 minutes if able.
- pressure-reducing devices for seating surfaces. Do not use donut-type devices.
- Consider postural alignment, distribution of weight, balance and stability, and pressure relief when positioning individuals in chairs or wheelchairs.
- Use a written plan.

#### Skin Care and Early Treatment (see Early Treatment Guidelines 1, 2, 3, 4, 6, 8, 9, pages 7-8)

- Inspect skin at least once a day.
- Individualize bathing schedule. Avoid hot water. Use a mild cleansing agent.
- Minimize environmental factors such as low humidity and cold air. Use moisturizers for dry skin.
- Avoid massage over bony prominences.
- Use proper positioning, transferring, and turning techniques.
- Use lubricants to reduce friction injuries.
- Institute a rehabilitation program.
- Monitor and document interventions and outcomes.

### 6. Moisture/Incontinence:

If there is moisture or incontinence, see:

#### Skin Care and Early Treatment (see Guideline 2, 5, page 7)

- Cleanse skin at time of soiling.
- Minimize skin exposure to moisture. Assess and treat urinary incontinence. When moisture cannot be controlled, use underpads or briefs that are absorbent and present a quick-drying surface to the skin.

### 7. Nutritional Deficit:

If there is a nutritional deficit, see:

#### Skin Care and Early Treatment (see Guideline 7, pages 7-8)

- Investigate factors that compromise an apparently well-nourished individual's dietary intake (especially protein or calories) and offer him or her support with eating.
- Plan and implement a nutritional support and/or supplementation program for nutritionally compromised individuals.

Risk should be periodically reassessed. Care should be modified according to the level of risk. Frequency of reassessment depends on patient status and institutional policy.