# Overview

## Introduction

On December 19, 1989, the Omnibus Budget Reconciliation Act (Public Law 101-239) added a new title IX to the Public Health Service Act establishing the Agency for Health Care Policy and Research (AHCPR). AHCPR's goal is to enhance the quality, appropriateness, and effectiveness of health care services and access to such services. Section 911 of the Act establishes within AHCPR the Office of the Forum for Quality and Effectiveness in Health Care. Section 912 directs the Forum to facilitate the development and periodic review and updating of:

Clinically relevant guidelines that may be used by physicians, educators, and health care practitioners to assist in determining how diseases, disorders, and other health care conditions can most effectively and appropriately be prevented, diagnosed, treated, and managed clinically.

The prediction, prevention, and early treatment of pressure ulcers was selected as one of seven topics for initial guideline development based on this mandate, legislative criteria for guideline topics, input from the Nursing Panel for Guideline Development, and the published report of a Consensus Development Conference on pressure ulcers by the National Pressure Ulcer Advisory Panel (NPUAP, 1989).

This guideline's purpose is to help identify adults at risk of pressure ulcers, to define early interventions for prevention, and to describe treatments for Stage I pressure ulcers. A pressure ulcer was defined by the panel as any lesion caused by unrelieved pressure resulting in damage of underlying tissue. The guideline is not intended as a basis for care of infants and children, nor do recommendations apply to persons with existing Stage II or greater pressure ulcers or to fully mobile persons. Individuals at risk may be seen in community, tertiary care, and other hospitals; in nursing homes and extended care facilities; and in the home.

Guideline recommendations are intended for clinicians who examine and treat persons at risk of developing pressure ulcers. They include family physicians, internists, geriatricians, nurses, and nurse practitioners, physical and occupational therapists, and dieticians in medical-surgical, acute care, rehabilitation, geriatric, home, and other settings. The recommendations may also be useful to patients and family members, health care administrators, policy analysts, and others.

Interventions considered by the panel included early detection maneuvers (risk assessment, skin inspection, and risk factor identification) and laboratory tests for screening of nutritional status. Treatments evaluated by the panel included those broadly conceptualized as pressure reduction and relief and strategies to maintain tissue tolerance. The panel did not consider interventions unless they were supported by two or more clinical studies or were recommended in current clinical practice.

Pressure ulcers usually occur over bony prominences and are graded or staged to classify the degree of tissue damage observed. The staging of pressure ulcers recommended for use by this panel is consistent with the recommendations of the National Pressure Ulcer Advisory Panel (NPUAP, 1989 Consensus Conference) as derived from previous staging systems proposed by Shea (1975) and the International Association for Enterostomal Therapy (IAET, 1988). The staging is as follows:

- Stage I: Nonblanchable erythema of intact skin; the heralding lesion of skin ulceration. Note: Reactive hyperemia can normally be expected to be present for one-half to three-fourths as long as the pressure occluded blood flow to the area (Lewis, and Grant, 1925). This should not be confused with a Stage I pressure ulcer.
- Stage II: Partial thickness skin loss involving epidermis and/or dermis. The ulcer is superficial and presents clinically as an abrasion, blister, or shallow crater.
- Stage III: Full thickness skin loss involving damage or necrosis of subcutaneous tissue that may extend down to, but not through, underlying fascia. The ulcer presents clinically as a deep crater with or without undermining of adjacent tissue.
- Stage IV: Full thickness skin loss with extensive destruction, tissue necrosis or damage to muscle, bone, or supporting structures (for example, tendon or joint capsule). Note: Undermining and sinus tracts may also be associated with Stage IV pressure ulcers.

Staging definitions recognize these assessment limitations:

- Identification of Stage I pressure ulcers may be difficult in patients with darkly pigmented skin.
- When eschar is present, accurate staging of the pressure ulcer is not possible until the eschar has sloughed or the wound has been debrided.

## Incidence and Prevalence

Both the incidence (new cases appearing during a specified period) and prevalence (a cross-sectional count of the number of cases at a specific point in time) of pressure ulcers are difficult to determine because of methodological barriers that prevent generalization from available data. These problems exist in data from acute care hospitals, long-term facilities, and home care settings. Methodological limitations to interpretation of incidence and prevalence studies were broadly categorized by the NPUAP Consensus Development Conference (NPUAP, 1989). These limitations are (a) difficulty comparing various populations (data collected in tertiary care hospitals are not likely to reflect community hospital populations), (b) data sources ranging from direct observation of patients by trained research personnel to retrieval of data from patient records, and (c) study methods confusing incidence and prevalence and including or excluding Stage I ulcers and segments of the institutional population.

The incidence of pressure ulcers in hospital settings ranged from 2.7 percent (Gerson, 1975) to 29.5 percent (Clarke, and Kadhom, 1988). Prevalence by hospital bed ranged from 4 percent (Ek, and Boman, 1982) to 69 percent (Ameis, Chiarcossi, and Jimenez, 1980). The prevalence for hospitalized patients varied between 3.5 percent (Shannon, and Skorga, 1989) and 29.5 percent (Oot-Giromini, Bidwell, Heller, et al., 1989). In the most extensive study of acute care facilities, Meehan (1990) surveyed 148 hospitals and found a prevalence of pressure ulcers of 9.2 percent.

Several special subpopulations may be at higher risk than the general hospital population. Richardson and Meyer (1981) reported a pressure ulcer prevalence of 60 percent in hospitalized quadriplegic patients. Versluysen (1986) found an incidence of 66 percent in elderly patients admitted for femoral fracture. Orthopedic patients may be at greater risk for pressure ulcer development because of immobility; orthopedic patients with fractures appear to be at greater risk than patients admitted for elective orthopedic procedures (Versluysen, 1985; Jensen, and Juncker, 1987). Although few studies have focused on the critical care population, the 33 percent incidence reported by Bergstrom, Demuth, and Braden (1987) and the 41 percent prevalence reported by Robnett (1986) indicate that this may also be a high-risk population.

Among persons in skilled care and nursing home-type facilities, the prevalence ranged from 2.4 percent (Petersen, and Bittmann, 1971) to 23 percent (Langemo, Olson, Hunter, et al., 1989,; Young, 1989). The few incidence studies in this population report rates in a comparable range (Powell, 1989,; Langemo, Olson, Hunter, et al., 1991,; Brandeis, Morris, Nash, et al., 1989, 1990). These data are particularly difficult to generalize to other skilled care and nursing home facilities because of the highly variable nature of case mix and staffing. Studies by Brandeis, Morris, Nash, et al. (1989, 1990) demonstrated that the incidence of pressure ulcers increases with length of stay. The prevalence and incidence of pressure ulcers in these facilities deserves further attention to determine the magnitude and cost of the problem and to project the resources needed to increase the effectiveness of patient care.

The prevalence of pressure ulcers among persons who are cared for in home settings with the supervision or assistance of professionals is not fully understood. Barbenel, Jordan, Nicol, et al. (1977) reported a prevalence of 8.7 percent of Stage II ulcers or worse; in a very small sample (N = 30), Clarke and Kadhom (1988) reported an incidence of 20 percent. The magnitude of the problem among home care patients requires further investigation.

In summary, the incidence and prevalence of pressure ulcers are sufficiently high to warrant concern. Methods for determining the actual incidence and prevalence are complicated by the lack of studies that are widely generalizable and sufficiently controlled in data acquisition methods and pressure ulcer classification systems to draw conclusions. Studies that use large data bases suffer from lack of control of the data acquisition skills of the observers and must be balanced with technically more accurate data acquisition using smaller samples. The staging system recommended by the NPUAP (1989) should be endorsed and used in future studies to increase the generalizability of data. A systematic assessment guide detailing the pressure ulcer sites should be used to prevent errors of omission in measurement. Knowledge of the incidence and prevalence of pressure ulcers by stage, type of health care facility, diagnosis, and mobility and other risk factor deficits will permit better planning for and allocation of services to vulnerable populations.

## Methodology for Guideline Development

Guideline development procedures followed the procedures recommended by AHCPR and Steven Woolf, MD, MPH, a consultant to the panel. Panel procedures were further influenced by JoAnn Horsley, PhD, RN, a consultant who was the principal investigator for The Conduct and Utilization of Research in Nursing (CURN), a project that was funded during the late 1970's. This pioneering work in research utilization developed practice protocols based on a critique of available research and synthesis of available knowledge (Haller, Reynolds, and Horsley, 1979).

The methodology recommended by AHCPR was used by the pressure ulcer panel to develop recommendations on the basis of (a) the clinical benefits and harms of potential interventions and (b) relevant health policy issues. The assessment of clinical benefits and harms was intended to determine which practices produce the best health outcome for patients in the aggregate sense. The assessment of health policy issues was intended to address resource constraints (for example, costs of interventions) and feasibility issues that might affect implementation of the panel's recommendations.

Panel members were appointed by AHCPR after a broad range of input was sought from professional and health care consumer organizations and individuals. At least one professional organization endorsed each panel member. The panel consisted of three physicians (family practice, dermatology, and gerontology), five nurses (rehabilitation, aging, acute care, enterostomal therapy, oncology, and management), one occupational therapist (rehabilitation), one basic scientist (plastic surgery research), one biomedical engineer (rehabilitation), and one consumer representative. Guidelines and standards have traditionally been based on the best judgment of a panel of experts. The pressure ulcer panel was charged with summarizing the scientific base to support guideline recommendations. It is no longer deemed sufficient to use the best judgment of experts without first understanding the scientific data base. For this reason, the National Library of Medicine (NLM) conducted a comprehensive literature review for the panel, which carefully scrutinized clinical benefits and harms and reviewed prevailing practice documented in professional standards and written reports. There was a comprehensive retrieval of published manuscripts and relevant unpublished material. Relevant literature was identified from computerized searches conducted in July and August of 1990 by NLM staff. Bibliographic data bases that were searched included MEDLINE and 20 other data bases. Through these mechanisms, the panel reviewed approximately 12,000 abstracts (including duplicates from several data bases). About 800 manuscripts were evaluated; 27 percent were research manuscripts.

The guideline was written after scientific evidence and expert or professional judgment had been evaluated and the harms and benefits of each recommendation considered. Recommendations were based first on the quality of the direct or indirect supporting evidence that an action would produce a favorable result. Second, the research base suggesting the direct or indirect result must have been replicated in a minimum of one study. It was preferred that multiple studies serve as the basis for recommendations (Haller, Reynolds, and Horsley, 1979). Third, recommendations were supported by common practice as reflected by review articles, chapters in textbooks, and the standards and guidelines of professional organizations. Expert opinion or professional judgment is an important part of guideline development because it is unlikely that there will be an adequate scientific data base to support each recommendation. When research evidence was lacking, expert opinion was used and documented as such.

Based on the experience of the Conduct and Utilization of Research in Nursing (CURN) project, guidelines are most effective when they are specific (Haller, Reynolds, and Horsley, 1979). For this reason, the panel attempted to be as specific as possible while allowing enough flexibility to respect expert judgment and patient preferences in individual cases.

Following completion of the guideline document's first draft, an open forum was held in Washington, D.C., on December 6, 1990. The forum had been announced in the Federal Register on November 23, 1990. All persons, organizations, and agencies with an interest in the pressure ulcer guideline were invited to attend and to present written or verbal testimony. A draft version of the document was then presented at a conference held on March 6-8, 1991 and sponsored by the National Pressure Ulcer Advisory Panel, the International Association for Enterostomal Therapy, and the Association of Rehabilitation Nurses (ARN). Over 175 persons attended. The conference enabled participants to provide feedback on the content and format of the document through formal and informal response papers. Sessions that organized input from hospitals, extended care, and home care representatives also provided input. These suggestions were incorporated into a revised version of the guideline document.

Next, peer review was undertaken. Peer reviewers were selected from:

- Professional organizations, which were invited to disseminate the guideline to as many reviewers as deemed appropriate and to collate responses for return of a single document to the panel.
- Participants in the open forum and NPUAP conference and other professional participants who volunteered.
- Individuals who wrote, phoned, or otherwise identified themselves as willing to review.

A list of potential peer reviewers was maintained throughout the project. Final selection of peer reviewers considered representation from both a broad range of professional disciplines and clinical practice arenas.

Peer reviewers were asked specifically to evaluate the comprehensiveness of the literature review and identify any manuscripts that were omitted or inappropriately or incompletely cited, evaluate the conclusions based on the literature review, and evaluate the guideline recommendations based on practical realities. Comments from peer reviewers were distributed to the panel. Panel deliberations regarding these comments resulted in guideline revisions as appropriate.

The panel subjected the pressure ulcers guideline to pilot review before providing it to AHCPR. Pilot review comprised three specific activities. First, health care agencies were invited to examine the hypothetical impact of the guideline on their setting. Cost, resources, and practicability of implementation were considered. Second, health care agencies were invited to examine the guideline, test it informally on a small number of patients in the practice setting, and provide feedback to the panel. Third, selected sites were asked to provide a somewhat more formal evaluation of the guideline, as time allowed, setting in motion a plan for implementing guideline recommendations. This more in depth testing provided additional useful information prior to final revisions.

Pilot review sites, like peer reviewers, were selected from a list of names submitted to the panel during the process of guideline development. Key organizations representing classifications of health care settings were asked to conduct pilot reviews. A broad diversity of clinical representation was sought. University hospitals, community hospitals, and small rural hospitals were selected, as well as nursing home chains, small private nursing homes, and visiting nurse and other home health care agencies. Attention was also given to regional distribution.

After the results of pilot review were collated and appropriate responses incorporated, the guideline was submitted to AHCPR.