# Attachments

## Management of Urinary Incontinence in Primary Care

## Sample Bladder Record

Sample Bladder Record

NAME:
DATE:
INSTRUCTIONS: Place a check in the appropriate column next to the time you urinated in the toilet or when an incontinence episode occurred. Note the reason for the incontinence and describe your liquid intake (for example, coffee, water) and estimate the amount (for example, one cup).
Time interval | Urinated in toilet | Had a small incontinence episode | Had a large incontinence episode | Reason for incontinence episode | Type/amount of liquid intake
6-8 a.m.
8-10 a.m.
10-noon
Noon-2 p.m.
2-4 p.m.
4-6 p.m.
6-8 p.m.
8-10 p.m.
10-midnight
Overnight
No. of pads used today: | | | No. of episodes:
Comments:

## Sample Incontinence Monitoring Record for Hospital and Nursing Home Patients