# Abbreviations

ADL: Activities of Daily Living

BPH: Benign prostatic hyperplasia

BUN: Blood urea nitrogen

CMG: Cystometrogram

DHIC: Detrusor hyperactivity with impaired bladder contractility

DI: Detrusor instability

EMG: Electromyography

HCFA: Health Care Financing Administration

ISD: Intrinsic sphincter deficiency

MDS: Minimum Data Set

MMSE: Mini-Mental State Examination

NSAID: Nonsteroidal anti-inflammatory drug

PME: Pelvic muscle exercise

PPA: Phenylpropanolamine

PVR: Postvoid residual volume

RAI: Resident Assessment Instrument

RAP: Resident Assessment Protocol

SUI: Stress urinary incontinence

TCA: Tricyclic antidepressant

UI: Urinary incontinence

UPP: Urethral pressure profilometry

UTI: Urinary tract infection