# Foreword

Urinary incontinence (UI) affects approximately 13 million Americans in community and institutional settings. Despite its prevalence, and an estimated annual cost of more than $15 billion, most affected individuals do not seek help for incontinence, primarily because of embarrassment or because they are not aware that help is available. When individuals do seek help, evidence exists that practitioners are hesitant or ill prepared to discuss, diagnose, or treat the problem.

A number of Federal and private organizations have provided research funding for the study of UI. Data from these studies indicate that treatment of UI is effective in most people, but there is an increased need for efforts to inform and educate the public and health care providers about the condition. Furthermore, there are wide variations in the actual costs and methods of providing care for UI, in the actual costs per procedure, and the charges within each diagnostic group.

It is expected that UI will continue to be a significant health care problem in the elderly and institutionalized populations, and will increase as the population of America continues to age.

This Clinical Practice Guideline Update addresses major evaluative, diagnostic, treatment, and management issues of UI. It was developed under the sponsorship of the Agency for Health Care Policy and Research (AHCPR), Public Health Service, U.S. Department of Health and Human Services. To develop the guideline, AHCPR convened a multidisciplinary, expert panel of physicians, nurses, other allied health care providers, and consumers. The panel first undertook an extensive and interdisciplinary clinical review of current needs, therapeutic practices and principles, and emerging technologies for diagnosis and treatment of UI. Second, the panel conducted a comprehensive review of the field to define the existing knowledge base and critically evaluate the assumptions and common wisdom in the field. Third, the panel initiated peer review of guideline drafts with intended users in clinical sites. Comments from these reviews were assessed and used in developing the guideline.

This is an update of the Clinical Practice Guideline on Urinary Incontinence in Adults, first published in March 1992. This update reflects new research findings and experience with emerging technologies for UI diagnosis and treatment, and provides specific recommendations for diagnosing and managing adult patients with UI.

Urinary Incontinence in Adults Guideline Update Panel