# Acknowledgments

The panel wishes to acknowledge several other consultants and technical advisors. They have provided external reviews for the combined analyses, consultation during panel meetings, and testimony during the open forum. They are:

- Consultants
- Patricia Burns, PhD, RN, FAAN
- Ananias Diokno, MD
- Teh-Wei Hu, PhD
- Donna Katzman McClish, PhD
- Thelma Joan Wells, PhD, RN, FAAN
- Matthew Zack, MD, MPH

- Technical Advisors
- Jerry Blaivas, MD
- Kari Bo, PE, PT, PhD
- Carol Brink, MPH, RN
- Cheryl Gartley
- Linda Cardozo, MD
- Alan Cottenden, PhD
- Molly Dougherty, PhD, RN, FAAN
- Shelia Fiers, RN, BSN, CETN
- Katherine Jeter, EdD
- Rhonda Kotarinos, MS, PT
- Deborah Lekan-Rutledge, MSN, RN, C
- Christine Norton, RN
- Mary H. Palmer, RNC, PhD, FAAN
- Neil Resnick, MD
- Carolyn Sampselle, PhD, RN, FAAN
- Alan Wein, MD

Many other organizations and individuals also made significant contribution during the development of this guideline. Although they are too numerous to mention here, the Contributors section, which appears later in this document, lists individual consultants, peer reviewers, and support staff. Publication of this guideline would not have been possible without their collaborative efforts.