# Urinary Incontinence in Adults Guideline Update Panel

- J. Andrew Fantl, MD (Co-Chair)
- Diane Kaschak Newman, RNC, MSN, FAAN (Co-Chair)
- Joyce Colling, PhD, RN, FAAN
- John O.L. DeLancey, MD
- Christopher Keeys, PharmD
- Richard Loughery, FACHA
- B. Joan McDowell, PhD, RN, FAAN
- Peggy Norton, MD
- Joseph Ouslander, MD
- Jack Schnelle, PhD
- David Staskin, MD
- Jeannette Tries, MS, OTR
- Vernon Urich, MD
- Sharon H. Vitousek, MD
- Barry D. Weiss, MD
- Kristene Whitmore, MD