# Education

## Public Education

Increased efforts to inform and educate the public about incontinence are essential. (Strength of Evidence = C.)

The public should be aware that incontinence is not inevitable or shameful but is treatable or at least manageable. (Strength of Evidence = C.)

Patient education needs to be comprehensive and multidisciplinary so as to explain all management alternatives. (Strength of Evidence = C.)

More research is needed to test the effectiveness of patient education activities. (Strength of Evidence = C.)

UI has the stigma of a socially unacceptable condition because of public lack of knowledge, misconceptions, and intolerance. This leads to personal isolation, social embarrassment, and delays in seeking medical advice. The public needs to know that many therapy and management problems surround UI (Burton, 1984; Goldstein, Hawthorne, Engeberg, et al., 1992; Herzog, Fultz, Normolle, et al., 1989; Joseph Rowntree Foundation, 1991; Holst and Wilson, 1988; Lagace, Hansen, and Hickner, 1993; Norton, MacDonald, Sedgwick, et al., 1988; O'Brien, Austin, Sethi, et al., 1991; Thomas, Plymat, Blannin, et al., 1980). Since 1983, national and international groups have concluded that there is a lack of professional and public education about UI (Association for Continence Advice, 1993; Jeter and Gartley, 1994; Kings Fund, 1983; National Institutes of Health, 1990). In 1988, the National Institutes of Health (NIH) Consensus Development Conference on UI in adults concluded that there was a greater need for efforts to inform and educate the public about this common problem. However, specific education interventions were not designated. The research necessary to evaluate education programs specific for incontinence is lacking.

Since the 1988 NIH conference, public knowledge has increased somewhat through publication of the 1992 AHCPR guideline documents and the efforts of two self-help groups, Help for Incontinent People and the Simon Foundation for Continence. More than 1.3 million English-version and 125,000 Spanish-version AHCPR patient guides have been distributed since their 1992 release. The Continence Foundation offers public access to services and information in the United Kingdom. Education advocacy and support groups bridge the gap between the public, affected individuals, and the health care providers and provide multimedia resources, patient and health professional education, and patient referral services. Patients often turn to these groups for guidance and support. Letters to syndicated columnists Ann Landers and Abigail Van Buren (Dear Abby) about UI have also gained widespread reader attention. Product manufacturers are addressing UI through extensive media advertisements and publication of brochures, and in the United Kingdom some companies sponsor telephone helplines. One pharmaceutical company's pilot media program has attracted considerable public interest in seeking more information and medical advice on UI (Association for Continence Advice, 1993).

Healthy People 2000 recommends an increase in public education and self-help resources as well as a reduction in major activity limitations for the management of chronic conditions U.S. Department of Health and Human Services, 1990). However, these efforts need to be increased so that the entire public is made aware that incontinence is neither inevitable nor shameful but instead treatable or at least manageable. The public should be encouraged to seek professional information and advice. Unfortunately, information alone is not enough to change behavior. A comprehensive and effective patient education program needs to determine what the patient wants to know as well as what the health care provider determines is necessary.

Two reports assess the information needs of the incontinent person (Jeter and Wagner, 1990; Moore and Saltmarche, 1993). An information-seeking instrument developed by Moore and Saltmarche has been tested for reliability and validity and will be used for data collection to guide patient education.

Because the problem of UI crosses all social, economic, racial, and gender lines, educational programs need to be diverse, person- or consumer-friendly, and understandable in a variety of media. Teaching should be a collaborative effort involving medical, nursing, and allied health care providers working with education and communication experts, and local, regional, and national government employers. Education should be individualized for each patient but also should include family and friends who may be involved in the patient's care. Sharing experiences and education in a nonthreatening atmosphere is a major technique of UI support groups and should be encouraged. Research to test educational effectiveness of these programs should be encouraged, developed, and evaluated, because specific research on UI patient teaching is lacking.

From available research, the main teaching goals that should be implemented are that (1) misconceptions about UI should be corrected, and information that incontinence can be helped should be disseminated to the widest possible audience; (2) patients with UI who seek health care need customized yet flexible patient teaching resources because of cultural, age, and educational differences; and (3) the learning experience should provide problem-solving and self-management skills that are integrated into daily living patterns. To accomplish these goals, a multimedia approach is needed that can provide information and education about UI misconceptions and management options at the learner's pace. Examples include use of public service announcements, public talk shows or interviews, health lectures, and toll-free telephone messages or helplines. Programs can be facilitated through pamphlets, booklets, audiotapes, videotapes, movies, slides, slidetapes, film strips, computers, and interactive videodiscs. For example, an interactive laser disc program on treatment options for benign prostate hypertrophy led to a 60-percent drop in requests for prostatectomy (Borzo, 1994). The applicability of such a program for incontinence should be tested. It is essential that teaching effectiveness be evaluated because instructing patients is insufficient (Garding, Kerr, and Bay, 1988).

Similarly, knowledge on ways to prevent UI is lacking. Examples of possible preventive maneuvers include teaching women about gestational and postpartum PME, and teaching both men and women about scheduled voiding and proper bladder-emptying techniques. Other health promotion models describe primary prevention mechanisms including education programs regarding estrogen use to treat atrophic vaginitis, postmenopausal changes of the genitourinary tract, and the elimination of fluids with diuretic effects (Palmer, 1994). When the public learns to better manage UI and to seek early treatment, the personal, social, psychological, and economic costs of the condition will decrease.

## Professional Education

Education about UI evaluation and treatment should be included in the basic curricula of undergraduate and graduate training programs of all health care providers. Continuing education programs on UI should be offered to all health care providers. (Strength of Evidence = C.)

Education about UI for professionals, paraprofessionals, and survey teams is urgently needed. First and foremost, information about UI should be included in the curricula of undergraduate and graduate health care professional schools. Schools of nursing and physical therapy and for physician assistants should consider educating specialists on incontinence care who can then serve as expert advisers to other health care providers regionally, on the State level, in teaching hospitals, and in every nursing home.

To increase practitioners' knowledge of UI, continuing education courses should focus on the types of incontinence and on appropriate, state-of-the-art diagnostic techniques and treatments (Morishita, Uman, and Pierson, 1994). Professionals most likely to provide care to UI patients should be encouraged to attend these courses. Education on UI should also be part of the training programs for paraprofessional students, such as licensed vocational nurses, practice nurses' aides, and auxiliary workers in the community. Because UI is a major problem in long-term care settings, special emphasis should be directed to encouraging alliances among all professions responsible for the care of persons with UI. In this setting, education may need to be geared to the different levels of nursing personnel. Palmer (1995) in a survey about nurses' knowledge and beliefs about continence interventions in one nursing home found differences between attributions of cause of UI between LPNs and RNs, indicating a need for continued education.

A survey of physicians in an Oklahoma demonstration project revealed that 17 percent of medical physicians had seen or read the 1992 AHCPR guideline on UI. This group included internists (113), obstetricians and gynecologists (134), family practitioners (115), and urologists (14) (McFall, Yerkes, Belzer, et al., 1994). Many physicians do not discuss nonsurgical therapy alternatives with their patients because they have a selection bias. UI should be included in the curricula along with practical applications and demonstrations that the majority of UI patients can be managed in primary care settings.

Major nursing organizations recognize the significance of UI and the vital role of nursing professionals. Plans are ongoing for development of continence care nursing practice guidelines. Emulation of the United Kingdom Continence Advisors program is a plausible solution but necessitates government involvement. A number of education organizations exist in the United Kingdom that provide training and education and whose members work in collaboration with other health care providers (Association for Incontinence Advice 1993). Education and competency training for nurse practitioners in UI assessment and management can duplicate the Continence Advisors program. Conferences similar to the Multispecialty Nursing Conference on UI (held in Phoenix, Arizona, January 1994) can offer indepth education and provide training on technical skills so that these individuals can become productive and valued members of the UI team.

UI outcome measures need to be developed so that nursing home surveyors are better able to assess the effectiveness of interventions for UI in this setting.