# Treatment of Urinary Incontinence

The three major categories of treatment are

- Behavioral.
- Pharmacologic.
- Surgical.

Treatment options including their risks, benefits, and outcomes should be discussed with the patient so that informed choices can be made. As a general rule, the first choice should be the least invasive treatment with the fewest potential adverse complications that is appropriate for the patient. For many forms of UI, behavioral techniques meet these criteria. However, an informed patient's preference must be respected. A combination of surgical, behavioral, and pharmacologic interventions may be appropriate, but more research is required to determine the optimum treatment combinations for specific patient groups.

The role of other measures and supportive devices used in the management or treatment of UI is considered at the end of this chapter.

## Behavioral Techniques

Behavioral techniques decrease the frequency of UI in most individuals when provided by knowledgeable health care providers, have no reported side effects, and do not limit future treatment options. Behavioral therapies can be divided into (1) caregiver-dependent techniques for patients with cognitive and motor deficits and (2) those requiring active rehabilitation and education techniques. These distinctions are arbitrary, however, and any individual's ability to actively participate varies on a continuum from complete dependence to full participation in the most complex behavioral therapies. For example, physically impaired patients who are cognitively intact may benefit from bladder training, pelvic muscle exercises (PMEs), and biofeedback therapy, but may depend on caregivers for assistance to the toilet.

Behavioral techniques are listed below in the order of those requiring passive involvement to those requiring active participation:

- Toileting assistance -- routine/scheduled toileting, habit training, and prompted voiding.
- Bladder retraining.
- Pelvic muscle rehabilitation -- PMEs, PMEs and bladder inhibition augmented by biofeedback therapy, PMEs augmented with vaginal weight training, and pelvic floor electrical stimulation.

All behavioral techniques involve educating the patient, the caregiver, or both, and provide positive reinforcement for effort and progress. Behavioral techniques should be offered to motivated individuals who wish to avoid more invasive procedures or dependence on protective garments, external devices, and medications. Behavioral techniques have few reported side effects and do not limit future treatment options. Behavioral techniques can increase patient understanding of lower urinary tract function and the environmental factors affecting symptoms. These techniques can improve control of detrusor and pelvic muscle function. They generally require patient or caregiver involvement and continued practice. If motivated, most people treated with behavioral techniques show improvement ranging from complete dryness to decreased incontinence episodes. Improved bladder control can occur even in the cognitively impaired individual (Colling, Ouslander, Hadley, et al., 1992; Engel, Burgio, McCormick, et al., 1990; McCormick, Cella, Scheve, et al., 1990; Schnelle, 1990). Behavioral techniques can also be used in combination with other therapies for UI.

Published results indicate that determining the precise level of effectiveness of behavioral interventions is limited by the following factors:

- Use of different outcome criteria.
- Variability in number, duration, and frequency of and adherence to treatment sessions.
- Variability of comprehensiveness in training procedures.
- Absence or variability in followup data.
- Concurrent application of multiple interventions that confound outcomes.
- Unspecified criteria for group assignment.
- Use of heterogeneous samples.
- Lack of measurement of independent variables.
- Uncontrolled inclusion of patients who had failed previous incontinence treatments.
- Lack of standardized terminology for the various behavioral techniques. (Because of the lack of standardized terminology, the reader must examine each study carefully and be alert to differences even in studies that appear to use the same terms.)

In general, however, studies show that behavioral interventions are effective in reducing incontinence. The cost of behavioral treatments compared with other treatments has not been studied, but two reports showed that the behavioral techniques enabled a considerable number of patients to avoid or postpone surgery (Cammu, Van Nylen, Derde, et al., 1991; Mouritsen, Frimodt, and Moller, 1991).

### Assessment Before Behavioral Intervention

Before implementing behavioral therapy, patients should undergo the basic evaluation. Behavioral approaches must be tailored to the patient's underlying problem, such as bladder training or habit training for urge UI and pelvic muscle rehabilitation for SUI. Patients with overflow UI are not primary candidates for behavioral intervention.

### Toileting Assistance

Toileting assistance interventions include routine or scheduled toileting, habit training, and prompted voiding.

Routine or scheduled toileting should be offered to incontinent patients on a consistent schedule. This technique is recommended for patients who cannot participate in independent toileting. (Strength of Evidence = C.)

Routine or scheduled toileting is provided by the caregiver on a fixed schedule at regular intervals. The caregiver takes the patient to void every 2-4 hours including at night. The goal is to keep the patient dry. No systematic effort is made to motivate the patient to delay voiding and resist urge, unlike in bladder retraining. In an uncontrolled, descriptive study of 161 male institutionalized patients, 20 patients who received a 4-week regimen of toileting every 2 hours eight times per day experienced an 85-percent improvement and were incontinent less than 20 percent of the time (Sogbein and Awad, 1982). In an uncontrolled, descriptive study of 20 females aged 24-94 years who were instructed to void every 2 hours regardless of urge for a period of 2 weeks, patients reported a 79-percent success rate (Godec, 1994). Burgio, Stutzman, and Engel (1989) studied 20 men postprostatectomy who followed a 2-hour voiding program for 2 weeks and reported a 33-percent increase in urgency, 29-percent decrease in stress UI, and no change in continual leakage.

Habit training is recommended for patients for whom a natural voiding pattern can be determined. (Strength of Evidence = B.)

Habit training is toileting scheduled to match the patient's voiding habits. One controlled study of habit training identified voiding patterns of 51 nursing home residents with an electronic monitoring device (Colling, Ouslander, Hadley, et al., 1992). The nursing home staff were taught to toilet the residents during the periods of greatest voiding frequency based on individual patterns identified by monitoring. A significant reduction in UI occurred during the 3-month intervention in 86 percent of the subjects, with one-third of this group showing 25 percent or greater improvement over baseline compared with an increase in UI observed in the control group. In addition, the volume of urine loss decreased significantly in the experimental group only. No side effects of habit training were reported. Nursing staff compliance was a problem, however, because of resistance to changes in care routines.

Habit training is an excellent technique for patients in the home living with a caregiver.

Prompted voiding is recommended in patients who can learn to recognize some degree of bladder fullness or the need to void, or who can ask for assistance or respond when prompted to toilet. Patients who are appropriate for prompted voiding may not have sufficient cognitive ability to participate in other, more complex behavioral therapies. (Strength of Evidence = A.)

The three major elements of prompted voiding are as follows:

- Monitoring -- The patient is checked by caregivers on a regular basis and asked to report verbally if wet or dry.
- Prompting -- The patient is asked (prompted) to try to use the toilet.
- Praising -- The patient is praised for maintaining continence and for trying to toilet.

Prompted voiding has been shown to be effective in dependent or cognitively impaired nursing home incontinent patients (Schnelle, 1990; Hu, Igou, Kaltreider, et al., 1989; Burgio, McCormick, Scheve, et al., 1994; McCormick, Burgio, Engel, et al., 1992). Used as a supplement to habit training, prompted voiding reinforces discrimination of continence status, the need to urinate, and requests for toileting assistance from caregivers.

Four clinical trials, three controlled (Creason, Grybowski, Burgener, et al., 1989; Hu, Igou, Kaltreider, et al., 1989; Schnelle, 1990) and one uncontrolled (Burgio, McCormick, Scheve, et al., 1994), evaluated prompted voiding in nursing homes. The combined trials used prompted voiding for 251 residents and demonstrated significant reductions in incontinence with no reported side effects. An average reduction of 0.8-1.8 incontinence episodes per patient per day was reported. In contrast, the baseline number of incontinence episodes in control group subjects of approximately 4.5 times per 12-hour period remained unchanged over the course of the clinical trial. Residents with lower voiding frequencies (less than four in a 12-hour period) and those who toileted appropriately more than 75 percent of the time during a brief 2- to 6-day prompted voiding trial were the most likely to show long-term benefits with prompted voiding.

A clinical trial in seven nursing homes reported that nursing staff were able to maintain improved resident continence levels for 6 months in 76 residents who were identified as highly responsive to prompted voiding (Schnelle, Newman, White, et al., 1993). An earlier study showed that the behavioral training resulted in an estimated 76 percent savings per day per patient, and the investigators recommended that such training be instituted early after admission to maximize savings (Schnelle, Sowell, Hu, et al., 1988). Because nursing home staff administer the prompted voiding and habit training protocols, program success relies on training, compliance, and incentives for active staff participation. A 3-hour prompted voiding schedule can improve dryness in residents with mild to moderate UI (Burgio, McCormick, Scheve, et al., 1994).

### Bladder Training

Bladder training is strongly recommended for management of urge (DI) and mixed incontinence. Bladder training is also recommended for management of SUI. (Strength of Evidence = A.)

Bladder training (also termed "bladder retraining") has many variations but generally consists of three primary components:

- Education.
- Scheduled voiding with systematic delay of voiding.
- Positive reinforcement.

The education program usually combines written, visual, and verbal instruction that addresses the physiology and pathophysiology of the lower urinary tract. A bladder training program requires the patient to resist or inhibit the sensation of urgency, to postpone voiding, and to urinate according to a timetable rather than according to the urinary urge (McCormick and Burgio, 1984).

Bladder training may involve tactics that help distend the bladder, such as adjustment in fluid loads and delayed voiding to provide progressively larger voiding volumes and longer intervals between voids (Keating, Schulte, and Miller, 1988).

Initially, the interval goal is usually set between 2 and 3 hours or determined by the patient's present interval, and is not enforced during sleeping hours. The voiding schedule progressively increases the interval between mandatory voids with concomitant distraction or relaxation techniques. The patient is thus taught to delay voiding when the urge to void occurs. If the patient is unable to delay voiding between scheduled toileting times, the schedule is adjusted and the interval time is reset from the time of the last void. Another method is to keep the prearranged schedule and disregard the unscheduled void between schedules. The training may continue for several months, during which time the therapist provides positive reinforcement and instruction.

Bladder training has been used primarily to manage UI caused by DI. This form of training has few side effects but is difficult to implement in cognitively impaired persons. It may not be successful in frail, elderly patients.

Several reports demonstrate that bladder training is effective in reducing UI (Fantl, Wyman, McClish, et al., 1991; Ferrie, Smith, Logan, et al., 1984; Pengelly and Booth, 1980). Fantl, Wyman, McClish, et al. (1991) conducted a controlled, randomized study of 131 women with sphincteric incompetence and unstable detrusor function, 123 of whom had some followup data. Subjects receiving treatment participated in a bladder training program that included behavioral strategies to decrease urge, patient education, and a schedule of voiding. Of the 60 women in the treatment group, 12 percent became dry and 75 percent had at least a 50-percent reduction in the number of incontinent episodes. The magnitude of the effect was somewhat larger in the women with DI. The effect of bladder training was maintained after 6 months. Control subjects did not have significant changes in incontinent episodes. To date, no urodynamic variable has been shown to relate directly to the observed beneficial clinical effects.

### Pelvic Muscle Rehabilitation

PMEs may be used alone or augmented with bladder inhibition biofeedback therapy or with vaginal weight training. Pelvic floor electrical stimulation is another method of pelvic muscle rehabilitation. Health care providers must teach patients the correct method of distinguishing and contracting the pelvic muscles through digital vaginal examination to verify appropriate muscle use, verbal feedback, or use of vaginal weights and biofeedback therapy to ensure accurate performance (Benvenuti, Caputo, Bandinelli, et al., 1987; Bump, Hurt, Fantl, et al., 1991; Burns, Marecki, Dittmar, et al., 1985; Dougherty, Abrams, and McKey, 1986; Keating, Schulte, and Miller, 1988).

#### Pelvic Muscle Exercise

Teaching women PMEs may prevent UI. (Strength of Evidence = C.)

Teaching exercises to strengthen pelvic muscles may decrease the incidence of UI. (Strength of Evidence = C.)

PMEs are strongly recommended for women with SUI. (Strength of Evidence = A.)

PMEs are also recommended in men and women in conjunction with bladder training for urge incontinence. (Strength of Evidence = B.)

PMEs may also benefit men who develop urinary incontinence following prostatectomy (Strength of Evidence = C.)

PMEs, also called Kegel exercises and pelvic floor exercises, are performed to strengthen the voluntary periurethral and perivaginal muscles (i.e., voluntary urinary sphincters and levator ani) that contribute to the closing force of the urethra and to the support of the pelvic visceral structures.

The first step in pelvic muscle re-education is to establish better awareness of pelvic muscle function. PMEs are performed by "drawing in" or "lifting up" of the perivaginal muscles and anal sphincter as if to control urination or defecation with minimal contraction of abdominal, buttock, or inner thigh muscles (Rose, Baigis-Smith, Smith, et al., 1990). Patients are generally told to sustain a contraction for at least 10 seconds, followed by an equal period of relaxation. The exercises should be performed about 30-80 times a day for at least 8 weeks and may need to be continued indefinitely. Elderly patients may require a longer time to train. In general, an individualized program of exercises and repetitions should be tailored to enhance muscle strength progressively (Ferguson, McKey, Bishop, et al., 1990). To condition the muscle to contract with increases in intra-abdominal pressure, patients should be taught to contract the pelvic muscles before and during situations when leakage may occur.

The specific effects of PMEs on actual lower urinary muscle function is not completely understood; some studies show a relationship between changes in various measures of pelvic floor strength, such as anal sphincter strength or maximum urethral closure pressure, and reduction in incontinence (Benvenuti, Caputo, Bandinelli, et al., 1987; Bo, Hagen, Kvarstein, et al.,1990; Ferguson, McKey, Bishop, et al., 1990; Dougherty, Bishop, Mooney, et al., 1993).

PMEs are indicated for women with stress incontinence and can reduce urgency and prevent urge UI ( Burgio and Engel, 1990; Burgio, Robinson, and Engel, 1986; Burgio, Stutzman, and Engel, 1989; Burton, Pearce, Burgio, et al., 1988; Castleden, Duffin, Asher, et al., 1985; Klarskov, Nielsen, Kromman-Andersen, et al., 1991; McDowell, Burgio, Dombrowski, et al., 1992). They may be effective in reducing incontinence following prostatic surgery in men, but to date have only been tested for postprostatectomy in conjunction with a biofeedback component (Burgio, Stutzman, and Engel, 1989). PMEs are effective in reducing UI even after multiple surgical repairs in women ( Baigis-Smith, Smith, Rose, et al., 1989; Brink, Wells, and Diokno, 1987; Burgio and Engel, 1990; Castleden, Duffin, and Mitchell, 1984; Ferguson, McKey, Bishop, et al.,1990; Heller, Whitehead, and Johnson, 1989; Henalla, Kirwan, Castleden, et al., 1988; Pearson and Droessler, 1988; Rose, Baigis-Smith, Smith, et al., 1990; Stoddart, 1983).

The effects of PME alone have been well documented in the medical literature. A summary of outcome findings from well-conducted studies follows.

Dougherty, Bishop, Mooney, et al. 1993) studied 65 women 35-75 years of age (mean age 51.3) and obtained a 62-percent reduction in UI episodes, and Ferguson, McKey, Bishop, et al. (1990)studied 20 women and demonstrated a 56- to 58-percent reduction in leakage as measured by 24-hour pad test using audiotape instruction in PME. Telephone contact and ongoing use of a bladder record may have contributed to the greater success found in these studies compared with others using a one-time instruction session.

To date, the most effective use of PME has been reported in an uncontrolled study by Benvenuti, Caputo, Bandinelli, et al. 1987), who provided 20 sessions of PME and other behavioral strategies and an intensive home program for a total of 10 contact hours to 20 women aged 35-65 years (mean age 50.8). In addition to a 95-percent reduction in incontinent episodes, significant changes were also reported FUL and MUCP at rest and during maximal voluntary contraction. A significant clinical benefit was consistent with changes in several physical measures of bladder function.

In a randomized clinical trial comparing PME and phenylpropanolamine hydrochloride (PPA), PME was found to be an effective alternative treatment for SUI comparable to PPA (Wells, Brink, Diokno, et al., 1991). Of the 54 subjects who completed the exercise program and the 64 who completed the drug protocol, 77 percent of the exercise subjects and 84 percent of the drug subjects reported improvement. The PME protocol involved 6 months of active PME taught with only written instruction, followed by monthly monitoring visits. The PPA was administered in doses of 50 mg daily for 2 weeks, increasing to twice daily if wetting continued. Adherence to the drug treatment was greater than to the exercise protocol.

Indications are that the intensity of the exercise program affects physiological and functional outcomes. Bo, Hagen, Kvarstein, et al. (1990) found that 52 subjects of mean age 45.9 years (range 24-64) randomized into a group receiving ongoing guidance in performing maximum contractions of the pelvic muscle that increased in intensity over 6 months reportedsignificantly greater reduction in incontinence and changes in physiological measures of pelvic floor strength compared with a group that received only a single session of instruction and a home exercise program. The group receiving the ongoing instruction reported a 60.1-percent cure/improvement rate compared with 17.3 percent attained in the home exercise group. This work also indicates a possible systematic relationship between symptom reduction and objective physical changes. Based on the data presented (Benvenuti, Caputo, Bandinelli, et al., 1987; Elia and Bergman, 1993; Mouritsen, Frimodt, and Moller, 1991), there is evidence that pelvic muscle re-education has the potential to change muscle physiology. Standards for assessment of change in pelvic muscle function have yet to be established, however.

PME also appears to be effective in the treatment of older adults. Flynn, Cell, and Luisi (1994) provided treatment for transient UI in 37 older adults receiving home nursing care (mean age 76) and behavioral strategies that included education in the maintenance of bowel regularity, bladder and habit training, fluid intake management, and PME. An 82.4-percent decrease in UI was attained with an average of five nursing visits. Because those patients with transient UI were not separated in the final analysis, the specific effect of the behavioral treatment is difficult to determine. Nonetheless, this report and others (Scheve, Engel, McCormick, et al., 1991) demonstrate the overall effectiveness of a well-directed nursing program, which includes PME for UI in the homebound and long-term chronically ill patients.

Summary of findings. Evidence demonstrates that patients require repeated guidance over an extended period of time to derive optimal benefit from PME. Kegel himself recommended that patients be seen weekly to ensure that the exercises were being performed correctly. Further controlled studies are needed to demonstrate the most efficient method of teaching PME, exercise prescription, and the conditions in which biofeedback provides an added benefit to PME alone. It should also be noted that the majority of the research on PME is in women only.

#### PME and Bladder Inhibition Augmented by Biofeedback Therapy

Pelvic muscle rehabilitation and bladder inhibition using biofeedback therapy are recommended for patients with stress UI, urge UI, and mixed UI. (Strength of Evidence = A.)

Some type of biofeedback device is often used to assist patients to gain function and pelvic muscle awareness { Burns, Pranikoff, Nochajski, et al., 1990). The aim of biofeedback therapy, which uses electronic or mechanical instruments to relay information to patients about their physiologic activity, is to improve bladder dysfunction by teaching people to change physiologic responses that mediate bladder control (Burgio and Engel, 1990). Auditory or visual display of this information forms the core of biofeedback procedures (Schwartz, 1995). Biofeedback for UI typically uses single measurement (surface, needle, vaginal, or anal probe) EMG or manometric methods. Biofeedback using multimeasurement feedback methods involves simultaneous measurement of pelvic and abdominal/detrusor muscle activity. Biofeedback should be used in conjunction with other behavioral techniques such as PME and bladder training. As with all of the behavioral techniques, successful application of biofeedback depends greatly on the knowledge and skill of the health care provider, whose knowledge must include familiarity with evaluation techniques, anatomic and physiologic correlates of the different forms and symptoms of bladder dysfunction, instrumentation, and behavioral principles that guide the procedure.

Studies on the various applications of biofeedback combined with behavioral treatment report a range of 54-87 percent improvement in incontinence across various patient groups using different biofeedback and behavioral procedures. Some biofeedback protocols use only one measure for reinforcement of pelvic muscle contraction, whereas others use up to three, and include measures of abdominal and detrusor activity. The biofeedback protocol that has been associated with the largest and most consistent symptom reduction is one that reinforces pelvic muscle contraction concurrently with inhibition of abdominal and detrusor contraction. Reports using this multimeasurement method show a 75.9-82 percent reduction in UI across six studies involving 166 subjects Burgio, Robinson, and Engel, 1986; Burgio, Stutzman, and Engel, 1989;(Burgio, Whitehead, and Engel, 1985; Burton, Pearce, Burgio, et al., 1988; McDowell, Burgio, Dombrowski, et al., 1992). The presumed benefit of the multimeasurement procedure is that it reinforces pelvic floor contraction directly with moment-to-moment feedback, which characterizes for the patient the quality and intensity of the contraction. Without biofeedback, weak pelvic muscles may provide limited kinesthetic feedback to the desired contraction, and as a result the patient uses an attenuated internal reference to upgrade muscle contractions. Combining bladder and sphincter biofeedback also allows teaching pelvic muscle contraction in response to increasing bladder volume and observed detrusor activity.

In a controlled study, Burgio, Robinson, and Engel (1986) found that 13 subjects (mean age 47.9) receiving multimeasurement biofeedback reduced incontinence by 75.9 percent compared with a 51-percent reduction obtained in 11 subjects (mean age 40.7) who received only verbal feedback and instruction for PME with digital palpation. The multimeasurement biofeedback method has also been used successfully in the treatment of UI in postprostatectomy patients with urge and intermittent stress incontinence (Burgio, Stutzman, and Engel, 1989). However, another study demonstrated that when subjects complained primarily of urge incontinence, no benefit was obtained with the addition of biofeedback to behavioral training and PME, which was provided by a well-trained clinician over an average of five clinic sessions (Burton, Pearce, Burgio, et al., 1988). The results of this study should be interpreted with caution, however, because the groups differed in severity before treatment.

Several studies have also demonstrated significant reductions in UI associated with neurologic disease and in the frail elderly using a combination of multimeasurement biofeedback and other behavioral techniques such as bladder training (McDowell, Engberg, Weber, et al., 1994; Middaugh, Whitehead, Burgio, et al., 1989; O'Donnell and Doyle, 1991). Because multimeasurement biofeedback can provide specific reinforcement for pelvic muscle contraction that is isolated from counterproductive abdominal contraction, it is assumed that awareness of pelvic muscle contraction can be achieved more efficiently than from vaginal palpation alone.

In contrast to multimeasurement methods, the reduction in number of pad changes per 24 hours ranged from 43 to 54 percent when single-measurement biofeedback is used, when excluding a subgroup who had received only one biofeedback session (Wilson, Faragher, Butler, et al., 1987). This improvement was attained in an approximate average of 11 sessions (0.5 to 1.5 hours each). Another study (Susset, Galea, and Read, 1990) used single-channel biofeedback over six weekly clinic visits and a home trainer with which the subjects practiced daily. These subjects demonstrated an 87-percent reduction of leakage on pad test, suggesting that a home training device may provide an added benefit to clinic biofeedback visits, especially when only single-channel biofeedback is used.

In a randomized controlled study, Burns, Pranifoff, Nochajski, et al. (1993) studied 135 women (age range 55-75 years) with primary stress incontinence in three groups. One group received PME, and another group received single-measurement EMG biofeedback to perivaginal contraction for 20 minutes per week. The two treatment groups demonstrated a 54-61 percent reduction in incontinent episodes, compared with a 6-percent reduction of incontinence in the control group, but no difference between the two treatment groups was found. The improvements were maintained over a 6-month followup, and patients with moderate-to-severe symptoms showed even more improvement in the posttreatment phase. This study demonstrated that PME reduces incontinence and provided evidence that symptom severity has a role in response.

Further research is needed to determine which biofeedback protocols ensure that optimal outcomes are achieved in individual conditions and what methods provide the most valid measures of pelvic muscle function. The multimeasurement biofeedback appears to produce greater reduction in incontinence compared with PME alone or single measurement biofeedback. It is not known, however, to what degree detrusor or intra-abdominal pressure biofeedback individually contributes to the outcomes reported.

Summary of findings. Overall, the literature indicates that PME and other behavioral strategies, with or without biofeedback, can "cure" or reduce incontinence. Maximum benefit is derived from any pelvic muscle rehabilitation and education program when ongoing reinforcement and guidance are provided. Also, the intensity of the exercise program seems to influence both functional and physiological outcomes, and multimeasurement biofeedback protocols seem to yield the greatest and most consistent reductions in UI (Bo, Hagen, Kvarstein, et al., 1990; Burgio, Robinson, and Engel, 1986; Elia and Bergman, 1993; McDowell, Burgio, Dombrowski, et al., 1992).

#### Pelvic Muscle Exercises Augmented with Vaginal Weight Training

Vaginal weight training is recommended for SUI in premenopausal women. (Strength of Evidence = B.)

Specially designed vaginal weights for strengthening the pelvic muscles can augment PME. The patient receives a set of vaginal weights of identical shape and volume but of increasing weight (20-100 grams). As part of a structured progressive resistive exercise program, women insert the weight intravaginally, with the tapered portion resting on the superior surface of the perineal muscle and attempt to retain it by contracting the pelvic muscles up to 15 minutes. The weight is worn while the patient is ambulatory, and the exercise is done twice daily. The hypothesized mechanism of action is that the sustained contraction required to retain the weight increases the strength of the pelvic muscles, and the weight is assumed to provide heightened proprioceptive feedback to desired pelvic muscle contraction.

Available literature on this technique includes observations made in premenopausal women with SUI. Initial observations from four studies including 103 premenopausal women indicate subjective "cure" or greatly improved status of 68-80 percent after 4-6 weeks of treatment (Bridges, Denning, Olah, et al., 1988; Olah, Bridges, Denning, et al., 1990; Peattie and Plevnik, 1988; Peattie, Plevnik, and Stanton, 1988; Wilson and Borland, 1990). Objective outcome measures included reduction of urine loss on pad test, improvement in ability to hold heavier weights intravaginally, increased pelvic muscle strength (perineometer), and significant reduction in incontinence episodes. There were minimal or no adverse reactions. However, in several studies, PMEs were performed at the same time.

Although vaginal weight training may be useful in the treatment of stress incontinence, issues of applicability to other populations, particularly postmenopausal women with pelvic organ prolapse or other comorbid conditions, must be evaluated in terms of treatment protocols and long-term effects.

#### Pelvic Floor Electrical Stimulation

Pelvic floor electrical stimulation has been shown to decrease incontinence in women with SUI. (Strength of Evidence = B.)

Pelvic floor electrical stimulation may be useful for urge and mixed incontinence. (Strength of Evidence = B.)

Pelvic floor electrical stimulation (nonimplantable) produces a contraction of the levator ani, external urethral and anal sphincters, accompanied by a reflex inhibition of the detrusor; this activity depends on a preserved reflex arc through the sacral micturition center (Vodusek, Plevnik, Vrtacnik, et al., 1988). Nonimplantable pelvic floor electrical stimulation uses vaginal or anal sensors or surface electrodes (Vodusek, Plevnik, Vrtacnik, et al., 1988). Adverse reactions are minimal and include pain and discomfort. Studies vary regarding the type and placement of electrodes; frequency, duration, and amplitude of voltage; and whether the stimulation was phasic, intermittent, or continuous. Several of these studies address long-term followup with reports that the effects for cured or improved patients ranged from 54 to 77 percent (Bent, Sand, Ostergard, et al., 1993; Bergmann and Eriksen, 1986; Blowman, Pickles, Emery, et al., 1991; Caputo, Bensen, McClellan, et al., 1993; Eriksen, 1990; Eriksen, Bergmann, and Mjolnerod, 1987; Eriksen, Bergmann, and Eik-Nes, 1989; Esa, Kiwamoto, Sugiyama, et al., 1991; Fall, Ahlstrom, Carlsson, et al., 1986; Fossberg, Sorensen, Ruutu, et al., 1990; Green and Laycock, 1990; Hahn, Sommar, and Fall, 1991; Lamhut, Jackson, and Wall, 1992; Leach and Bavendam, 1989; Lose, Andersen, and Kristensen, 1986; McIntosh, Frahm, Mallett, et al., 1993; Meyer, Dhenin, Schmidt, et al., 1992; Eriksen and Mjolnerod, 1987; Nakamura, Sakurai, Tsujimoto, et al., 1986; Nakamura, Sakurai, Sugao, et al., 1987; Ohlsson, Fall, and Frankenberg-Sommar, 1989; Plevnik, Joney, Vrtacnik, et al., 1986; Sand, Richardson, Staskin, et al., 1995; Wilson, 1990; Zollner-Nielsen and Samuelsson, 1992).

Two randomized controlled trials have been conducted. Using active and placebo perianal surface patch neurostimulation for SUI in patients, Blowman, Pickles, Emergy, et al. 1991) reported a "cure" or improvement rate of 86 percent in the active group (N=7) and 33 percent in the placebo group (N=6). Electrical stimulation was not used as a single therapy, however; both groups also received instruction in PME. Using active and inactive vaginal plug devices in 52 women with SUI, Sand, Richardson, Staskin, et al. (1995) reported objective "cure" or improvement in 48 percent of the active device group and in 13 percent of the placebo group. Active device patients had significant improvements in UI episodes, leakage volume, and vaginal muscle strength and in subjective improvement measures when compared with the placebo group.

In other studies with similar settings, anal or vaginal plug devices were used for maximal electrical stimulation for 4 weeks to 3.5 months, 20 minutes to 20 hours/day. "Cure" or improvement rates ranged from 48 to 94 percent in 842 patients with stress, urge, or mixed incontinence. The effects of therapy were sustained 6 weeks to 2 years in 54-77 percent of patients, especially if patients continued to do PME after treatment (Bergman and Eriksen, 1986; Blowman, Pickles, Emery, et al., 1991; Bridges, Denning, Olah, et al., 1988; Caputo, Bensen, McClellan, et al., 1993; Eriksen, Bergmann, and Eik-Nes, 1989; Eriksen, Bergmann, and Mjolnerod, 1987; Eriksen and Eik-Nes, 1989; Esa, Kiwamoto, Sugiyama, et al., 1991; Fossberg, Sorensen, Ruutu, et al., 1990; Kunkle, Payne, and Whitmore, 1993; Meyer, Dhenin, Schmidt, et al., 1992; Plevnik, Joney, Vrtacnik, et al., 1986; Sand, Richardson, Staskin, et al., 1995; Zollner-Nielsen and Samuelsson, 1992). One study of cognitively impaired patients in a nursing home showed no significant effect of stimulation, with a trend toward increased wetness (Lamhut, Jackson, and Wall, 1992).

Summary of findings. Research indicates that pelvic floor electrical stimulation can significantly reduce UI in women with SUI, and may be effective in men and women with mixed and urge UI. Stimulation may be effective when augmented with other pelvic muscle rehabilitation therapies. Minimal adverse side effects occur with this treatment. Treatment using stimulation requires monitoring by a health care provider to determine effectiveness. Further research is needed to determine the efficacy of pelvic floor stimulation used alone or in combination with other therapies. Standardization of the parameters of the techniques used, such as that proposed by the International Continence Society, is necessary to allow further comparison of study results.

## Pharmacologic Treatment[a,b]

[a] Of the pharmacologic treatments discussed in this chapter, only oxybutynin and flavoxate have been officially approved by the FDA for the indicated use. The remainder are not approved but are commonly used. [b] Imipramine is officially approved by the FDA for enuresis in children but not adults.

Several medications have proven to be beneficial for treating UI, although their risk-to-benefit ratios are difficult to gauge precisely because of deficiencies in study design. Some of the limitations of published trials include variable inclusion and exclusion criteria or inadequate (small) sample size; inconsistent definition of outcome criteria; short study durations; fixed drug dosages that may have been excessive or inadequate; analyses confounded by other interventions such as behavioral manipulations; and limited compliance data and nonuniform methods for collecting, reporting, and comparing side effects. Summarized below are data derived from randomized controlled trials of orally administered medications, vaginally administered medications, or both, used to treat UI. Recommendations pertaining to the benefits, risks, and utility of pharmacologic therapies are noted, including the strength of evidence.

### Urge Incontinence: Detrusor Instability

The following pharmacologic agents are reported to be useful in DI as observed in clinical practice. (Strength of Evidence = B.) Anticholinergic agents: oxybutynin, dicyclomine hydrochloride, and propantheline. Tricyclic antidepressants: imipramine, doxepin, desipramine, and nortriptyline.

#### Anticholinergic Agents

Anticholinergic agents are the first-line pharmacologic therapy for patients with DI. (Strength of Evidence = A.)

When pharmacologic therapy is to be used for patients with DI, oxybutynin is the anticholinergic agent of choice. The recommended dosage is 2.5-5 mg taken orally three or four times per day. (Strength of Evidence = A.)

Propantheline is the second-line anticholinergic agent in the treatment of patients with DI who can tolerate the full dosage. The recommended dosages are 7.5-30 mg administered three to five times per day; higher dosages (15-60 mg qid) may be required. (Strength of Evidence = B.)

Flavoxate is not recommended for the treatment of patients with DI. (Strength of Evidence = A.)

Anticholinergic agents are effective as treatment for UI because they block contraction of the normal bladder and probably the unstable bladder as well. All anticholinergic drugs are contraindicated in patients with documented narrow-angle, but not wide-angle, glaucoma.

Oxybutynin has both anticholinergic and direct smooth muscle relaxant properties. Seven randomized controlled studies of the use of this agent for UI were identified. Oxybutynin proved superior to placebo in six studies of middle-aged outpatients, reducing incontinence frequency by 15-58 percent over the response to placebo (Holmes, Montz, and Stanton, 1989; Moore, Hay, Imrie, et al., 1990; Riva and Casolati, 1984; Tapp, Cardozo, Versi, et al., 1990; Thuroff, Bunke, Ebner, et al., 1991; Zeegers, Kiesswetter, Kramer, et al., 1987). In two of these studies, 43 percent and 67 percent of subjects became subjectively continent, a much better result than occurred with placebo (Moore, Hay, Imrie, et al., 1990; Riva and Casolati, 1984). Only one study reported a benefit with a dosage of 15 mg tid-qid Holmes, Montz, and Stanton, 1989 ), whereas a second showed no improvement over placebo (Thuroff, Bunke, Ebner, et al., 1991). In the only trial that failed to note a benefit, oxybutynin was used less frequently (5 mg bid) in elderly nursing home residents (Zorzitto, Holliday, Jewett, et al., 1989). Oxbutynin has also been effective and well tolerated when instilled into the bladder of study patients, primary those with neuropathic bladder (Mizunaga, Miyata, Kaneko, et al., 1994).

Side effects were noted in all studies and included dry skin, blurred vision, change in mental status, nausea, constipation, and marked xerostomia (dry mouth). Severity increased with dosage, with severe xerostomia occurring in 84 percent of subjects receiving 5 mg of oxybutynin four times per day (Tapp, Cardozo, Versi, et al., 1990).

Propantheline is the prototype for anticholinergic agents used for urologic conditions. No agent better approximates atropine's effect on the bladder in vitro, although its central nervous system side effects are less marked. Moreover, propantheline is inexpensive and has been widely used over time.

Despite propantheline's success in uncontrolled case series, only five adequately controlled trials could be identified Blaivas, Labib, Michalik, et al., 1980; Dequeker, 1965; Holmes, Montz, and Stanton, 1989; Thuroff, Burke, Ebner, et al., 1991; Zorzitto, Jewett, Fernie, et al., 1986), three of which included only elderly nursing home residents with advanced dementia. Only one study reported a benefit with a dosage of 15 mg tid-qid (Holmes, Montz, and Stanton, 1989). Two of the nursing home studies evaluated higher dosages of propantheline (30 mg qid; 15 mg tid + 60 mg at bedtime (hs)) and found that incontinence frequency was reduced by 13-17 percent over placebo -- a small but statistically significant improvement in both studies Dequeker, 1965; Zorzitto, Jewett, Fernie, et al., 1986). In one of these trials, side effects were reported in half of the subjects, one-fifth of whom withdrew because of severe side effects Zorzitto, Jewett, Fernie, et al., 1986); no side effects were reported in the trial using the 60 mg hs dosage. In a dose titration study, dosages up to 60 mg qid were associated with complete response in 25 of 26 patients (Blaivas, Labib, Michalik, et al., 1980).

In addition to urinary retention, side effects associated with propantheline, as with all anticholinergic agents, include visual blurring, xerostomia, nausea, constipation, tachycardia, drowsiness, and confusion; the most common of these was xerostomia.

Despite the lack of adequate trials, consensus among experts is that at least for less impaired patients who can tolerate full dosages, propantheline is effective (Andersson, 1988; Wein, 1990).

Dicyclomine hydrochloride is an anticholinergic agent with smooth muscle relaxant properties. Studies on the use of this drug for UI are limited, and the populations that have been studied were small. One pilot trial and one larger randomized controlled trial were identified Beck, Arnusch, and King, 1976; Castleden, Duffin, and Millar, 1987). In the larger study, 62 percent of subjects improved on dicyclomine 10 mg tid (90 percent of whom became continent) compared with 20 percent on placebo (65 percent of whom became continent); statistical significance was not specified, and side effects were not mentioned Beck, Arnush, and King, 1976). Results were similar in the smaller pilot study (Castleton, Duffin, and Millar, 1987).

Studies comparing dicyclomine with other anticholinergic agents are not available. This agent may be used as an alternative treatment for UI, however, pending further research. The dosage is 10-20 mg taken orally three times daily.

Flavoxate is a tertiary amine that has demonstrated smooth muscle relaxant properties in vitro. Although flavoxate is widely used for incontinence, only four randomized controlled studies of its efficacy for UI could be identified (Meyhoff, Gerstenberg, and Nordling, 1983; Robinson and Brocklehurst, 1983; Zeegers, Kiesswetter, Kramer, et al., 1987; Chapple, Parkhouse, Gardener, et al., 1990). None demonstrated a significant benefit. At present, this drug is not recommended for the treatment of UI.

Hyoscyamine and other oral anticholinergics are known to be used in clinical practice in the treatment of DI; however, no scientific literature that met the panel's criteria addressed the use of these agents for patients with UI. The panel therefore is not making recommendations regarding these drugs.

#### Calcium Channel - Blocking Agents

Influx of extracellular calcium is important for detrusor muscle contraction and can be blocked by calcium channel antagonists. Although such agents are often advocated for bladder storage disorders, only a few small, but favorable, case series were identified in the literature. No controlled studies could be found for marketed agents (e.g., nifedipine, diltiazem, verapamil). One placebo-controlled study of flunarizine that showed a positive effect was identified; however, in a subsequent 1-month controlled trial by the same investigators, its efficacy diminished, and the high (but unreported) rate of side effects led the investigators to temper their original enthusiasm Palmer, Worth, and Exton-Smith, 1981). At this time, these agents are not recommended for general use for the treatment of detrusor instability.

Terodiline. An investigational drug in the United States, terodiline possesses calcium channel - blocking and anticholinergic properties. It has demonstrated in vivo activity in the treatment of DI. However, recent reports of serious ventricular arrhythmias have resulted in its temporary removal from the European market and discontinuation of trials in the United States.

#### Tricyclic Agents

The use of tricyclic agents (TCAs) should be reserved for carefully evaluated patients. The usual oral dosages are 10-25 mg initially administered one to three times per day, but less frequent administration is usually possible because of the long half-life of these drugs. The daily total dosage is usually 25-100 mg. (Strength of Evidence = B.)

Although TCAs are widely used, they produce many adverse effects (e.g., cardiac and anticholinergic), with the risk more likely in elderly patients. Limited research on the use of TCAs is available. Only three randomized controlled studies were identified. One conducted with psychiatric inpatients in whom the type of UI was not established showed that imipramine, desipramine, and nortriptyline each resulted in a statistically significant reduction in the number of "wet nights" (Milner and Hills, 1968). Side effects were rare and minor except for paralytic ileus in one case.

The other two studies, one using doxepin Lose, Jorgensen, and Thunedborg, 1989) and the other imipramine (Castleden, Duffin, and Gulati, 1986), documented decreases in incontinence frequency. However, the results were statistically significant only for reducing nocturnal incontinence and overall patient preference for doxepin. Side effects in these studies included fatigue, xerostomia, dizziness, and blurred vision in the doxepin group and nausea and insomnia in the imipramine group.

#### Nonsteroidal Anti-Inflammatory Drugs

Nonsteroidal anti-inflammatory drugs (NSAIDs) are not recommended for the primary treatment of DI. (Strength of Evidence = C.)

NSAIDs are theorized to be effective for UI because of their inhibition of prostaglandin "synthetase," which interferes with prostaglandin-mediated bladder contractions. However, limited research on the use of NSAIDs for patients with UI is available. Two controlled trials in women have been conducted (Cardozo and Stanton, 1979; Cardozo, Stanton, Robinson, et al., 1980). In a non-placebo-controlled trial, patients receiving indomethacin 100 mg po bid experienced comparable resolution of UI compared with those receiving bromocriptine (Cardozo and Stanton, 1979). A placebo-controlled trial demonstrated 55-percent continence with flurbiprofen 50 mg po tid versus 29 percent with placebo (Cardozo, Stanton, Robinson, et al., 1980). In both studies, side effects were frequent, although no patient stopped use of NSAIDs. When NSAIDs are used, close monitoring for drug toxicity (e.g., gastrointestinal hemorrhage, renal dysfunction) should be performed, especially in elderly patients.

#### Other Drugs of Possible Benefit

Other drugs used for detrusor instability include a beta-adrenergic agonist (terbutaline) (Lindholm and Lose, 1986) and a spinal synaptic inhibitor (baclofen) (Taylor and Bates, 1979). Limited studies and clinical experience with these agents suggest that further studies must be done before they can be recommended for general use.

Summary of findings. Pharmacotherapy, at least in short-term trials, appears to benefit some patients with UI due to detrusor instability. However, regardless of the agent chosen, involuntary bladder contractions are usually not abolished, the "warning time" between appreciation of the need to void and the onset of bladder contraction is usually not affected, the degree of improvement is modest, and "cure" is uncommon. In addition, many of these medications are costly, and most have bothersome side effects. These drugs should be used only in conjunction with a voiding schedule or behavioral intervention and only after other factors contributing to incontinence have been addressed.

To date, oxybutynin possesses the most favorable efficacy, safety, and pharmacokinetics profile of the agents for DI. However, selection of an agent must be individualized and based on patient considerations (i.e., contraindications) and cost as well as on drug considerations (i.e., kinetics, drug interactions, and side effects). For example, an antidepressant may be the preferred drug for UI in a depressed patient but not for a patient with orthostatic hypotension who is prone to falling. A drug with a rapid onset of action may be useful for a patient who desires protection only for certain events (e.g., going out for the afternoon), whereas a drug with a longer half-life may be preferable for a patient who desires continuous protection.

Regardless of the agent selected, the initial dosage should be relatively low. The dosage should be increased slowly, consistent with the drug's half-life, and titrated to balance efficacy with side effects. Patients must be closely monitored for urinary retention. Combining agents with different mechanisms of action may increase their efficacy and reduce side effects, but few relevant data are available. Although the long-term efficacy of bladder relaxants is largely unknown, Moore, Hay, Imrie, et al. (1990) have reported that once incontinence responded to pharmacologic and behavioral interventions, improvement persisted even if the medication was withdrawn after a few months.

### Stress Incontinence: Urethral Sphincter Insufficiency

The rationale for pharmacologic therapy for UI due to urethral sphincter insufficiency (stress incontinence, SUI) is based on selection of agents that affect the high concentration of alpha-adrenergic receptors in the bladder neck, bladder base, and proximal urethra. Sympathomimetic drugs with alpha-adrenergic agonist activity presumably cause muscle contraction in these areas and thereby increase bladder outlet resistance. Pharmacotherapeutic strategies that are designed to increase bladder outlet resistance include the use of drugs with direct alpha-adrenergic agonist activity, estrogen supplementation both for direct effect on urethral mucosal and periurethral tissues and for enhancement of alpha-adrenergic response, and beta-adrenergic-blocking drugs that may allow unopposed stimulation of alpha-receptor-mediated contractile muscle responses.

#### Alpha-Adrenergic Agonist Drugs

Phenylpropanolamine (PPA) or pseudoephedrine is the first-line pharmacologic therapy for women with SUI who have no contraindications for its use, particularly hypertension. The recommended dosage for PPA is 25-100 mg in sustained-release form, administered orally, twice daily. The usual dosage of pseudoephedrine is 15-30 mg, orally, three times daily. (Strength of Evidence = A.)

PPA in sustained-release form is the major alpha-adrenergic agonist drug studied in women with stress incontinence. Seven prospective randomized controlled studies of middle-aged, normotensive women with stress incontinence were reviewed. In three studies (Collste and Lindskog, 1987; Fossberg, Beisland, and Lundgren, 1983; Lehtonen, Rannikko, Lindell, et al., 1986) no patients became continent, but 31-45 percent of patients given PPA had decreased incontinence over placebo response (PPA minus placebo "improved" response). In four studies (Ek, Andersson, Gullberg, et al., 1978; Hilton, Tweddell, and Mayne, 1990; Walter, Kjaergaard, Lose, et al., 1990; Wells, Brink, Diokno, et al., 1991), 9-14 percent of women became dry, and 19-60 percent of patients experienced significant reduction of incontinence over the number of similar responses in the placebo group. In studies in which the improvement rate was reported, the reduction in leakage with PPA ranged from 31 to 60 percent over the response with placebo.

Side effects were minimal and included nausea, xerostomia, insomnia, rash, itching, and restlessness. PPA did not cause significant increases in blood pressure during the evaluation period.

Summary of findings. Pharmacologic therapy of incontinence caused by sphincter insufficiency (stress incontinence) using PPA appears to result in few cures or dryness (0-14 percent) but may cause subjective improvement in 20-60 percent of patients over placebo response. It is unclear whether patient age or the severity of leakage affects the likelihood of response. Possible side effects from alpha-adrenergic agonist drugs include anxiety, insomnia, agitation, respiratory difficulty, headache, sweating, hypertension, and cardiac arrhythmias, all of which may occur more commonly in elderly patients. The risk of PPA use in hypertensive women and its efficacy in women taking antihypertensive drugs have not been determined. PPA should be used with caution in patients with hypertension, hyperthyroidism, cardiac arrhythmias, and angina. The sustained-release form is advocated because of its routine use by investigators in clinical trials. Whether the immediate-release form produces similar results has not been established.

#### Estrogen Therapy

Estrogen (oral or vaginal) may be considered as an adjunctive pharmacologic agent for postmenopausal women with SUI or mixed incontinence. Conjugated estrogen is usually administered either orally (0.3-1.25 mg/day) or vaginally (2 g or fraction/day). Progestin (e.g., medroxyprogesterone 2.5-10 mg/day) may be given continuously or intermittently. (Strength of Evidence = B.)

Because the vagina and urethra are of similar embryologic origin, estrogen supplementation in postmenopausal women may restore urethral mucosal coaptation and increase vascularity, tone, and the alpha-adrenergic responsiveness of urethral muscle, which in turn may increase bladder outlet resistance and decrease stress incontinence. However, the exact role of estrogen, as well as its mechanism of action, is still unknown and deserves further research. Most clinical trials have been conducted with estrogen products available abroad; but their data are included in this report because of the paucity of research using marketed products in the United States and the similarities between estrogens.

Estriol derivatives. Two studies of postmenopausal women with stress incontinence compared effects of placebo and estriol, 4 mg/day, on continence ( Samsioe, Jansson, Mellstrom, et al., 1985; Walter, Kjaergaard, Lose, et al., 1990). Results showed that 0-14 percent of patients on estriol became dry, and 29 percent of patients experienced improved continence compared with patients who received placebo. One study showed that the response to estriol was significantly better than to placebo (Walter, Kjaergaard, Lose, et al., 1990), whereas the other study showed that the response to active drug was not significantly better than to placebo (Samsioe, Jansson, Mellstrom, et al., 1985). In the latter study, 66 percent of patients with UI reported improvement.

A trial of quinestradol, an estriol derivative, in female incontinent nursing home residents did not result in continence, but 89 percent of patients had a significant reduction of leakage episodes while taking quinestradol compared with 0 percent while on placebo (Judge, 1969).

Estrone derivatives. A 3-month prospective study of postmenopausal stress-incontinent women who received placebo or piperazine estrone sulfate for 3 weeks with one drug-free week per cycle revealed that subjective and objective improvements at 3 months were greater, but not statistically significant, while on estrogen (Wilson, Faragher, Butler, et al., 1987).

Fantl, Cardozo, McClish, et al. (1994) provided a meta-analysis from 6 randomized controlled trials and 17 uncontrolled clinical series. Favorable effects on incontinence in postmenopausal women were found with estrogen therapy (P<0.01 for all subjects and P< 0.05 for those with SUI).

Summary of findings. Limited evidence suggests that estrogen therapy by oral or vaginal administration may benefit some patients with SUI and mixed UI. Its effect on urge UI has not been reported in most of the available literature.

Other beneficial effects of long-term estrogen may include decreased risk of stroke, ischemic heart disease, and osteoporosis. Estrogen replacement should be given with a progestin when the uterus is present to avoid unopposed estrogen stimulation of the endometrium, particularly if prolonged therapy is anticipated. The dosages of estrogen and progestin used vary. Risks of estrogen therapy given in this manner include neoplasia of estrogen-responsive organs. Thus, estrogen therapy is contraindicated in patients with known or suspected cancer of the breast or uterus.

#### Alpha-Adrenergic Agonist and Estrogen Supplementation

Combination therapy of oral or vaginal estrogens and PPA is recommended in the treatment of SUI in postmenopausal women when initial single-drug therapy has proven inadequate. (Strength of Evidence = A.)

The rationale supporting combined estrogen supplementation and alpha-adrenergic agonist therapy in postmenopausal women with incontinence due to sphincteric insufficiency is based on an estrogen-induced increased number, sensitivity of alpha-adrenergic receptors in the urethra, or both, which potentiates the alpha-adrenergic contractile response to drug stimulation.

Review of four controlled studies that combined estrogen and alpha-adrenergic agonist therapy suggests that the combined therapy may be more effective than alpha-adrenergic agonist therapy alone (Ek, Andersson, Gullberg, et al., 1978, 1980; Hilton, Tweddell, and Mayne, 1990; Walter, Kjaergaard, Lose, et al., 1990). However, the studies are limited, and based on these results, combination therapy should be considered when initial single-drug therapy fails. The possible risks of alpha-adrenergic agonist drugs and estrogen do not appear to be increased when used together. Patients should be carefully monitored when combination therapy is prescribed, however.

#### Other Drugs of Possible Benefit

Imipramine is recommended as an alternative pharmacologic therapy for SUI when first-line agents have proven unsatisfactory. (Strength of Evidence = C.)

Imipramine. A tricyclic antidepressant that possesses both alpha-adrenergic agonist activity (presumably mediated by blocking reuptake of norepinephrine) and anticholinergic properties has been reported to benefit women with stress incontinence. In a nonrandomized, uncontrolled study, 30 women (28-64 years old) with pure stress incontinence received imipramine at 75 mg daily for 4 weeks; 21 of the 30 (70 percent) claimed continence (Gilja, Radej, Kovacic, et al., 1984). Side effects reported included nausea, insomnia, weakness, fatigue, and postural hypotension. Prospective controlled studies are not available, and thus further research is necessary.

The use of propranolol or other beta-blockers cannot be recommended for treatment of SUI because of lack of clinical experience and clinical studies. (Strength of Evidence = C.)

Propranolol. Limited research on the use of beta-blockers for treatment of SUI is available. In one uncontrolled study, a beta-adrenergic-blocking drug was reported to improve symptoms of SUI (Gleason, Reilly, Bottaccini, et al., 1974). The use of this and other beta-blockers cannot be recommended for treatment of incontinence at this time.

Antidiuretic hormone. Desmopressin (desmopressin diacetate arginine vasopressin (DDAVP)) is used mainly in the treatment of nocturnal enuresis and night-time polyuria. Available research on this drug has been conducted mainly in children and in patients with neuropathic conditions. Because few data exist in adults, DDAVP is not discussed in detail in this guideline.

## Surgical Treatment

The decision to perform surgery for the treatment of UI should be made only after a precise, focused assessment that includes a comprehensive clinical evaluation with an objective confirmation of the pathophysiologic diagnosis and severity of urinary loss, a correlation of the anatomic and physiologic findings with the surgical plan, an estimation of surgical risk, and an estimation of the impact of the proposed surgery on the patient's quality of life.

Several caveats must be considered when reviewing the literature on the surgical treatment of UI. Standards have not been established for describing the patient population, the type of incontinence, the methods for accurate diagnosis, the techniques of the surgical procedure, or the outcome in different domains (e.g., symptoms, anatomophysiologic outcomes, quantity of fluid loss, quality of life). There may be difficulty in comparing surgical procedures because of intentional modifications or variations in technique and the experience and expertise of the surgeon. Postoperative reporting is often biased by variations in the definitions for failure, improvement, and success, and similarly for the degree and incidence of operative morbidity, early and late complications, and length of followup. These variations make precise comparisons of studies including different surgeons performing the same procedure, or multiple surgeons performing different procedures, impossible. Retrospective comparison of different techniques may contain unknown selection biases. Prospective comparisons often include different surgeons with different degrees of experience and expertise. Terminology should be standardized for classification of incontinence, description and execution of surgical procedures, and reporting of surgical outcomes. In reports of series, complications should be reported individually, and the criteria for patient selection should be described. Comparison of different techniques should be made by prospective randomized studies using similar inclusion criteria for each technique.

This guideline is primarily directed toward the primary care provider, and the level of detail provided is not sufficient to direct surgical therapy. The inherent variability in surgical technique and the way in which operations are performed make it impossible to direct surgical practice in a guideline of this scope.

The objectives of surgical treatment of incontinence depend on the specific etiology. A given patient may have more than one etiology. In this guideline, each etiology is addressed separately. The purpose of a surgical procedure is to correct, compensate for, or circumvent the underlying pathology causing urinary loss. Stress incontinence in women may be caused by urethral hypermobility or ISD. Men with stress incontinence suffer solely from ISD. Inappropriate elevations in bladder pressure may result from uninhibited bladder contractions or a loss of bladder compliance. Poor bladder emptying that leads to retention may result from an impaired or absent bladder contraction or from outlet obstruction.

The surgical procedures described in this section are divided into three sections: (1) surgeries that increase outlet resistance and relieve SUI and ISD, (2) procedures that decrease detrusor instability and correct urge incontinence, and (3) operations that remove outlet obstruction, thereby correcting overflow incontinence or reversing detrusor instability that is secondary to the outlet obstruction.

Surgery is recommended for treatment of stress incontinence in men and women and may be recommended as first-line treatment for appropriately selected patients who are unable to comply with other nonsurgical therapies. (Strength of Evidence = B.)

### Stress Incontinence in Women: Hypermobility or Intrinsic Sphincter Deficiency

The surgical objective in cases of hypermobility is to improve the support of the sphincter unit without obstruction. On the other hand, the goal of surgery for ISD is to increase urethral coaptation and resistance. Although many operations result in both improved support and compression of the proximal urethra, a primarily supportive procedure is less likely to succeed for a patient with ISD than for a patient with only hypermobility.

#### Preoperative Evaluation

A preoperative evaluation is important to ensure proper patient selection and to determine the appropriate surgical procedure. The evaluation should include a comprehensive history, physical examination, urinalysis, urine culture, and measurement of PVR volume. It is important to document the incontinence objectively by direct observation of a positive stress test (direct visualization). Some multiparous women may have stress incontinence on physical examination but are not troubled by this; therefore, the patient should be asked if the incontinence visible on examination is the type of incontinence that led her to seek care. Because CMGs may be falsely negative in many women with DI, simply using a negative CMG to diagnose SUI is not acceptable. When further corroboration is needed, cystoscopy, a cystogram with straining, measurement of Valsalva leak point pressure, dynamic UPP, or a combination may be used.

Although patients with symptoms of DI may be more likely to remain incontinent after surgery, it is not clear whether a preoperative CMG to search for asymptomatic instability is necessary. If symptomatic instability is present, some health care providers may attempt behavioral or pharmacologic treatment before surgical correction of the stress incontinence. Others may not because many patients experience resolution of DI once stress incontinence is corrected. This decision must be made on an individual basis, using clinical judgment and considering the patient's informed preference.

To select the appropriate surgical procedure, one must assess the position of the urethra and the degree of axial urethral mobility by physical examination, cystogram, ultrasound, or cystoscopy. Factors that may be associated with an increased risk of failure, such as symptomatic DI, obesity, prior surgery, hypoestrogenism, chronic cough, strenuous physical activity, previous radiation therapy, advanced age, or poor nutrition, must be identified. Pelvic organ prolapse or other pathology that would require surgical treatment at the same time as the anti-incontinence procedure should also be identified. The approach required to treat the concurrent pathology will influence the choice of approach for the anti-incontinence procedure. The extent of the evaluation depends on the complexity of the presentation.

The degree of ISD should be assessed preoperatively using a combination of assessment tools. In the history, patients who have only hypermobility describe leakage with vigorous activity, whereas patients with ISD tend to have leakage with minimal activity. On physical examination, patients with incontinence due to hypermobility have descent of the urethra and bladder neck during stress maneuvers. On the other hand, reproducible demonstration of stress incontinence through a normally supported urethra is suggestive of ISD. Corroboration of ISD may be established by a variety of tests, including leak point pressure, passive urethral profilometry, imaging techniques such as fluoroscopy, and on occasion cystoscopic assessment. Most of these assessment tools do not provide a definitive diagnosis alone, especially if the patient has coexistent DI, which can cause a functional opening of the bladder neck at rest. Therefore, the entire clinical presentation must be considered.

#### Procedures for Hypermobility

After complete evaluation, if the primary pathophysiologic defect appears to be urethral hypermobility or displacement, three main types of procedures are used:

- Retropubic suspension.
- Needle bladder neck suspension.
- Anterior vaginal repair.

Retropubic or needle suspension is recommended for women with hypermobility when SUI is the primary indication for surgery. On the basis of greater efficacy, these procedures are recommended over anterior vaginal repair for hypermobility. (Strength of Evidence = B.)

Review of the available literature shows that in general retropubic and needle suspension procedures produce a superior result to that of anterior repair in "curing" UI. This analysis of results usually focuses exclusively on the symptom of stress incontinence and does not account for postoperative problems such as the new development of an enterocele or rectocele large enough to require surgery, persistent voiding difficulty, or DI. Therefore, although the reported cure rate for stress incontinence is high, the number of women with an entirely satisfactory outcome may not be. Treatment must be individualized for each patient as well as standard recommendations about which operation will be best. The option selected depends on the surgeon's training and expertise and on the presence of concurrent pathology that would require correction by a vaginal or abdominal approach.

For hypermobility with coexisting ISD the surgical procedure should stabilize the anatomic support and compress the urethra, which invariably means using one of the sling procedures (see Procedures for ISD below). The choice must be individualized for each patient. Women who have severely damaged urethras require special procedures such as urethral or bladder neck reconstruction, urethral substitution, continent vesicotomy, or urinary diversion.

Management must be individualized for women whose primary problem is prolapse of the pelvic organs but who have SUI or in whom temporary replacement of the prolapse during preoperative evaluation uncovers SUI. In these circumstances, a decision about the most appropriate anti-incontinence procedure to be combined with repair of the prolapse should account for the type of SUI present (hypermobility or ISD), the operation chosen to repair the prolapse (abdominal or vaginal), and additional morbidity from the continence operation weighed against the degree of incontinence. Preoperative urodynamic examination should be performed if this information is needed to choose the type of operation to be performed.

Retropubic suspension. Retropubic suspension procedures include several different techniques performed through a low abdominal incision (i.e., retropubic approach). All techniques have in common elevation of the lower urinary tract, particularly the urethrovesical junction, within the retropubic space. The procedures differ according to what structures are used to achieve the elevation. For the Marshall-Marchetti-Krantz procedure, the periurethral tissue is approximated to the symphysis pubis. For the Burch colposuspension, the vaginal wall lateral to the urethra and bladder neck is elevated toward Cooper's ligament. The paravaginal repair involves reapproximating the endopelvic fascia to the pelvic wall at the arcus tendineus.

To evaluate this category of procedures, 45 studies incorporating 3,882 patients were reviewed (Baker and Drutz, 1992; Beck, Thomas, and Maughan, 1968; Bergman, Ballard, and Koonings, 1989; Bergman, Koonings, and Ballard, 1989a; Bergman, Koonings, and Ballard, 1989b; Bergman, Koonings, and Ballard, 1989c; Brieger and Korda, 1992; Duncan, Nurse, and Mundy, 1992; Eriksen, Hagen, Eik-Nes, et al., 1990; Fall, Erlandson, and Pettersson, 1984; Ferriani, de Sa, de Moura, et al., 1990; Francis, Sand, Hamrang, et al., 1987; Goodno and Powers, 1992; Green, McGuire, and Lytton, 1986; Hilton and Stanton, 1983; Iosif, 1985; Jouppila, Kauppila, Ylikorkala, et al., 1977; Kiilholma, Makinen, Chancellor, et al., 1993; Kil, Hoekstra, Van der Meijden, et al., 1991; Korda, Ferry, and Hunter, 1989; Kujansuu, 1983; Langer, Ron-El, Newman, et al., 1988; Langer, Ron-El, Bukovsky, et al., 1988; Lockhart, Maggiolo, and Politano, 1983; Lose, Jorgensen, and Johnsen, 1988; Milani, Scalambrino, Quadri, et al., 1985; Morgan, 1973; Nielsen and Lundvall, 1973; Park and Miller, 1988; Penttinen, Kaar, and Kauppila, 1989; Penttinen, Lindholm, Kaar, et al., 1989; Pow-Sang, Lockhart, Suarez, et al., 1986; Richardson, Ramahi, and Chalas, 1991; Richmond and Sutherst, 1989a; Sand, Bowen, Ostergard, et al., 1988; Shull and Baden, 1989; Spencer, O'Conor, and Schaeffer, 1987; Stanton, Williams, and Ritchie, 1976; Stanton and Cardozo, 1979; Steel, Cox, and Stanton, 1985; Thunedborg, Fischer-Rasmussen, and Jensen, 1990; Van Geelen, Theeuwes, Eskes, et al., 1988; Vordermark, Brannen, Wettlauffer, et al., 1979; Wheelahan, 1990). Total "cure" rates averaged 79 percent, and 84 percent were "cured" or improved.

Overall complication rates reported for retropubic operations average 18 percent (6-57 percent). In the recent literature, complications reported among the studies of retropubic urethral suspensions were sparse, being included in only 6 of 13 papers with insufficient information and consistency to allow accurate statistical reporting. Wound infections, urinary retention, de novo DI, and dyspareunia were all noted in the 3-15 percent range. The cause of postoperative symptomatic enterocele/rectocele with anterior traction on the anterior wall seems to be most prominent after the Burch operation, occurring in up to 12 percent of patients (Kiilholma, Makinen, Chancellor, et al., 1993). Recently, some of these retropubic procedures have been performed laparoscopically.

Needle bladder neck suspension. Another type of anatomic correction employs needle suspension of the bladder neck. Variations of this procedure are all performed through a vaginal approach, and most utilize small suprapubic skin incisions (Cobb and Ragde, 1978; Gittes and Laughlin, 1987; Pereyra, Lebherz, Growdon, et al., 1982; Stamey, 1980; Raz, 1981). Anchoring tissues adjacent to the urethra and bladder neck are held by suspending sutures.

Of the 3,015 patients studied in the reviewed research, most had the Stamey procedure; the others had the Pereyra-Raz procedure Abbassian, 1989; Ashken, 1990; Benderev, 1992; Benson, Agosta, and McClellan, 1990; Bergman, Ballard, and Koonings, 1989; Bergman, Koonings, and Ballard, 1989a; Bergman, Koonings, and Ballard, 1989c; Bhatia and Bergman, 1985a; Bosman, Vierhout, and Huikeshoven, 1993; Cobb and Ragde, 1978; Dijkman and Friese, 1984; Duncan, Nurse, and Mundy, 1992; Foster and O'Reilly, 1989; Ganabathi, Abrams, Mundy, et al., 1992; Gaum, Ricciotti, and Fair, 1984; Griffith-Jones and Abrams, 1990; Hilton, 1989; Huland and Bucher, 1984; Jones, Shah, and Worth, 1989; Juma, Little, and Raz, 1992; Kil, Hoekstra, et al., 1991; Kirby and Whiteway, 1989; Kursh, 1992; Kursh, Angell, and Resnick, 1991; Leach and Raz, 1984; Lopez Lopez, Valdivia Uria, and Uca Terran, 1992; Loughlin, Whitmore, et al., 1990; Mundy, 1983; Netto, Lemos, Palma, et al., 1988; Nitti, Bregg, et al., 1993; Parra and Shaker, 1990; Penttinen, Kaar, and Kauppila, 1989; Pereyra, Lebherz, Growdon, et al., 1982; Pope, Shaw, Coptcoat, et al., 1990; Pow-Sang, Lockhart, Suarez, et al., 1986; Ramon, Mekras, and Webster, 1990; Raz, Sussman, Erickson, et al., 1992; Richardson, Ramahi, and Chalas, 1991; Shah and Holder, 1989; Spencer, O'Conor, and Schaeffer, 1987; Stamey, 1980; Varner, 1990; Walker and Texter, 1992; Wujanto and O'Reilley, 1989). For the combined series, 74 percent were continent postoperatively and 84 percent were "cured" or improved; followup varied. Complications included UTI, urinary retention longer than 3 weeks' duration, obstructive symptoms, suture abscess, wound infection or vaginal granuloma, vesicocutaneous fistula, hematoma, sutures pulling out of the vaginal fascia, sepsis, new onset of symptomatic DI, and prolonged suprapubic pain and de novo pelvic floor defects.

Anterior vaginal repair. The anterior vaginal repair category of treatments includes several modifications of the original Kelly plication. All techniques include some degree of dissection of the anterior vaginal wall from the overlying bladder base and urethra, and plication of the pubocervical fascia. The extent of the dissection and the location and extent of the placating (elevating) sutures vary substantially among these techniques. Although the success of these operations as a group is somewhat lower than retropubic or needle suspensions, some specific techniques achieve excellent success, on objective followup indicating the need to discriminate the actual technical details of each of these different operations before making generalizations (Beck, McCormick, and Nordstrom, 1991).

Review of 11 studies incorporating 957 patients reveals an overall "cure" rate of 65 percent (range = 31-91 percent) and a "cure" or improvement rate of 74 percent (range = 31-98 percent); followup varied (Beck, McCormick, and Nordstrom, 1991; Beck, Thomas, and Maughan, 1968; Bergman, Ballard, and Koonings, 1989; Bergman, Koonings, and Ballard, 1989c; Jouppila, Kauppila, Ylikorkala, et al., 1977; Kujansuu, 1983; Lose, Jorgensen, and Johnsen, 1988; Park and Miller, 1988; Stanton, Hilton, Norton, et al., 1982; Thunedborg, Fischer-Raumussen, and Jansen, 1990; Van Geelen, Theeuwes, Eskes, et al., 1988). Complication rates were provided for only two studies; the average was 14 percent.

#### Procedures for Intrinsic Sphincter Deficiency

Procedures for management of ISD include

- Sling procedures.
- Periurethral bulking injections.
- Placement of an artificial sphincter.

Sling procedures are recommended for women who have ISD with coexisting hypermobility or as first-line treatment for ISD. (Strength of Evidence = B.)

Periurethral bulking injections are recommended as first-line treatment for women with ISD who do not have coexisting hypermobility. (Strength of Evidence = B.)

Artificial sphincter is recommended for ISD patients who are unable to perform intermittent catheterization and have severe SUI that is unresponsive to other surgical treatments. Because of the high complication rate, this treatment is rarely used as primary therapy. (Strength of Evidence = B.)

Sling procedures. The various sling procedures all involve placing a sling, made of either autologous or heterologous material, under the urethrovesical junction and anchoring it to retropubic or abdominal structures or both. The operation can be performed through an abdominal approach, a vaginal approach, or a combined abdominal and vaginal approach. Sling operations are often performed in women with complicated incontinence, many of whom have failed previous attempts at surgical correction. The success and complication rate should be viewed with this fact in mind.

Data from a series of 9 studies of 434 patients with fascial slings indicated that 89 percent were "cured," and 92 percent were "cured" or improved (Beck, McCormick, and Nordstrom, 1988; Deppe, Castro-Marin, Nachamie, et al., 1978; Low, 1969; McGuire and Lytton, 1978; McIndoe, Jones, and Grieve, 1987; Narik and Palmrich, 1962; Ogundipe and Rosenzweig, 1992; Richmond and Sutherst, 1989a; Ridley, 1966). Combined analysis of 298 patients from six studies that used a synthetic sling indicated that 78 percent were "cured," and 84 percent were "cured" or improved (Brieger and Korda, 1992; Bryans, 1979; Kersey, 1983; Korda, Peat, and Hunter, 1989 ).

Although the total complication rate given for the fascial sling series was higher than that for the synthetic sling series, the synthetic sling caused more severe complications, many of which were directly attributable to local effects of the sling (i.e., erosion, nonhealing of the vaginal wall, abscess, vesicovaginal fistula). Fascial slings are preferable to synthetic slings because of the lower rate of local complications.

Data from 32 patients treated with the vaginal wall sling showed that 81 percent were dry, 9 percent were improved, and 9 percent showed no improvement (Ogundpipe and Rosenzweig, 1992; Ridley, 1966). Complications included urinary retention and new onset of irritative voiding symptoms.

Periurethral bulking injections involve the injection of materials such as polytetrafluoroethylene (PTFE), collagen, or autologous fat under cystoscopic guidance into an incompetent periurethral area. Patients being considered for periurethral collagen injection require a skin test for sensitivity to the material. Injection of the material appears to be technically easier because the number of patients requiring anesthesia or sedation is less than that reported with PTFE. The longevity of PTFE versus collagen has not been studied. Urinary tract infection and transient urethral irritation are the most common side effects after periurethral collagen injection. The procedures for periurethral bulking injections are described below in the section on male incontinence caused by ISD. In women, these injections are easily performed under local anesthesia. Combined data from 15 studies of 528 women indicate that after followup for up to 2 years 49 percent of patients were "cured" (range = 8-100 percent), and 67 percent were either "cured" or improved (Beckingham, Wemyss-Holden, and Lawrence, 1992; Berg, 1973; Deane, English, Hehir, et al., 1985; Eckford and Abrams, 1991; Harrison, Brown, and O'Boyle, 1993; Kiilhoma and Makinen, 1991; Lewis, Lockhart, and Politano, 1984; Lotenfoe, O'Kelly, Helal, et al., 1993; McGuire and Appell, 1994; O'Connell, McGuire, Aboseif, et al., in press; Santarosa and Blaivas, 1994; Schulman, Simon, Wespes, et al., 1983; Smart, 1991; Stricker and Haylen, 1993; Vesey, Rivett, and O'Boyle, 1988). Complications included urgency, UTI, and urinary retention.

Although documentation of teflon migration to the lung persisted (Claes and Stroobants, 1989) adverse reactions to this material in other sites has not been found. Increasing experience with collagen has established its efficacy in the short term, but, as with Teflon injection, long-term results beyond 5 years are not available.

Artificial sphincter. Artificial sphincter placement, described below in the section on ISD in men, has been used for women with ISD. Combined data from 8 studies of 192 women with ISD treated with artificial sphincter placement indicated that 77 percent were dry, and 80 percent were "cured" or improved (Appell, 1988; Light and Scott, 1985; Diokno, Hollander, and Alderson, 1987; Duncan, Nurse, and Mundy, 1992; Karram, Rosenzweig, and Bhatia, 1993; Motley and Barrett, 1990; Parulkar and Barrett, 1990; Webster, Perez, Khoury, et al., 1992). Complications included fluid leak, loose cuff, erosion or atrophy of the cuff site, tubing kink, and infection.

### Stress Incontinence in Men: Intrinsic Sphincter Deficiency

An underactive outlet in men may result from a congenital defect or from direct or indirect trauma to the anatomy or physiology of the bladder outlet. Direct trauma due to prostatectomy is the most common cause of sphincter insufficiency. Neurologic dysfunction (e.g., sympathetic innervation to the bladder neck, pelvic nerve to the intrinsic sphincter, pudendal nerve to the external sphincter) may be a primary or contributory etiology. Devascularization or fibrosis, most commonly following radiation therapy or surgery, may also contribute to decreased closure pressure of the bladder outlet. The high incidence of mixed incontinence requires that an alteration in bladder function be considered and diagnosed before surgical intervention for decreased outlet resistance. Postprostatectomy incontinence is not always due to sphincter insufficiency but sometimes to detrusor dysfunction or both. Patients must be evaluated for other possible causes of incontinence, including obstruction, DI, and poor bladder compliance.

The choices for surgical treatment of male sphincter insufficiency include

- Periurethral bulking injections.
- Placement of an artificial sphincter.

The sling procedure has been used only occasionally in men, and the information available is insufficient for providing effective recommendations at this time.

The preoperative evaluation may require a cystoscopy, and a simple cystometry or complex videourodynamic studies, depending on the suspected etiology. Special care and followup are required in neurologically impaired individuals due to a significant incidence of bladder compliance changes following therapy to increase outlet resistance. Before injection or sphincter implantation, it is advisable to wait at least 6 months to a year and to have the patient undergo behavioral and pharmacologic intervention during the intervening months. If an artificial sphincter is being considered, it is important to assess whether the patient has enough manual dexterity and ability to operate the device.

#### Periurethral Bulking Injections

Periurethral bulking injections are recommended as a first-line surgical treatment for men with ISD. (Strength of Evidence = B.)

Periurethral bulking injections can improve urinary loss in men with stress incontinence. The mechanism for improvement after injection therapy is still unclear but may reflect an improvement in urethral coaptation and possibly compression. Periurethral injections are less likely to succeed in male than in female patients and in all patients who have undergone pelvic radiation therapy or who have extensive periurethral scarring. Success is more common in patients who have stress incontinence after transurethral or open prostatectomy than in those after radical prostatectomy. The literature does not support the use of bulking agents in men with severe postprostatectomy incontinence (Appell, 1994). Experience and followup are limited for treatment by injections with collagen and fat, which are absorbed by patients over time. There are no randomized studies comparing the efficacy of different materials or of injection therapy with other forms of treatment. The analysis included 9 studies of 1,005 men treated with periurethral injection (Kaufman, Lockhart, Silverstein, et al., 1984; Corrie, Rodriguez, and Thompson, 1989; Deane, English, Hehir, et al., 1985; McGuire and Appell, 1994; Osther and Rohl, 1988; Smart, 1991; Stanisic, Jennings, et al., 1991; Politano, 1992; Santarosa and Blavias, 1994). Sample sizes ranged from a minimum of 3 to a maximum of 720. The mean age was 69 years, and mean followup time was 2.0 years. The "cure" rate was reported in eight studies and ranged from 0 to 66 percent, with a mean of 20 percent. The "cure"-improvement rate was reported in nine studies and ranged from 0 to 81 percent, with a mean of 42 percent.

Complications reported with PTFE included infection, urinary retention, fever, temporary erectile dysfunction, periurethral inflammatory reaction, extrusion of the material into the urine or perineal area, and burning sensation or perineal discomfort. Particles of PTFE have been found in patients' lungs after periurethral injection of PTFE, but the exact incidence and the clinical significance of this migration are not known.

#### Placement of an Artificial Sphincter

Artificial sphincter may be elected for ISD during the 6 months after prostatectomy. Behavioral intervention should also be tried during this period. (Strength of Evidence = B.)

Before periurethral injection therapy became available, placement of an artificial urinary sphincter was the most commonly used surgical procedure for the treatment of underactive outlet in men. Data on the current rate of comparative utilization of these two techniques are not available. Before implantation, urodynamic evaluation to confirm a stable, compliant, low pressure bladder is critical.

The analysis included 10 studies that presented data on 346 men, with sample sizes ranging from 11 to 96 (Brito, Mulcahy, Mitchell, et al., 1993; Gundian, Barrett, and Parulkar, 1989; Marks and Light, 1989; Nordling, Holm-Bentzen, and Hald, 1986; Lowe, Schertz, and Parsons, 1988; Malloy, Wein, and Carpiniello VL, 1989; Motley and Barrett, 1990; Schreiter, 1985; Wang and Hadley, 1991; Warwick and Abrams, 1990). The average age of the patients was 61.4 years. The "cure" rate was presented in nine studies and ranged from 33 to 88 percent, with a mean of 66 percent. The "cure" or improvement rate in the 10 studies ranged from 75 to 94.5 percent, with a mean of 85.3 percent.

Initial preoperative complications are mainly associated with urethral or bladder injury during implantation. Delayed complications included mechanical problems such as pump malfunction, fluid leak, or tubing kink; infection; or cuff-related site atrophy, incomplete compression, or erosion. In addition, urethral injury, pump erosion, and herniated reservoir were reported in fewer patients.

The utilization of the artificial urinary sphincter in patients after radiation therapy, cryotherapy, or pelvic fracture with urethroplasty is controversial because of concern about compromising the urethral blood supply. Also controversial is the use of intermittent catheterization after sphincter implantation. The experience of the implanting surgeon may be related to the incidence of complications.

### Urge Incontinence: Detrusor Instability

Use of surgical procedures in the management of urge incontinence is uncommon. Surgical treatment is usually considered only in highly symptomatic patients in whom nonoperative management has failed repeatedly.

The surgical procedures reviewed for the treatment of overactive bladder include

- Augmentation intestinocystoplasty or urinary diversion.
- Bladder denervation procedures.

Augmentation intestinocystoplasty is recommended for those patients with intractable, severe bladder instability or poor bladder compliance that is unresponsive to nonsurgical therapies. (Strength of Evidence = B.)

Urinary diversion is recommended in severe intractable cases of detrusor instability or poor bladder compliance that is unresponsive to other therapies. (Strength of Evidence = C.)

#### Augmentation Intestinocystoplasty or Urinary Diversion

Various surgical procedures have been proposed for treating intractable, severe bladder instability and poor compliance. Augmentation cystoplasty with a patch of detubularized intestine is usually considered the procedure of choice. Urinary diversion with a urostomy or continent urinary diversion may be utilized as a last resort.

The risks of augmentation cystoplasty, in addition to those of any bowel surgery, include voiding difficulties that may require catheterization, mucus or stone formation, metabolic decompensation, and the rare long-range possibility of tumor formation. Contraindications for augmentation cystoplasty include renal insufficiency, bowel disease, intractable urethral disease, and inability to perform self-catheterization.

Twelve articles were reviewed (Bramble, 1982; Fenn, Conn, German, et al., 1992; George and Russel, 1991; Kockelbergh, 1991; Linder, Leach, and Rax, 1983; Lockhart, Ellis, Helal, et al., 1990; Mundy and Stephenson, 1985; Raz, Ehrlich, Zeidman, et al., 1988; Robertson, Davies, et al., 1991; Sethia, Webb, and Neal, 1991; Sidi, Becher, Reddy, et al., 1990; Strawbridge, Kramer, Castillo, et al., 1989). The studies included 403 subjects, with sample sizes ranging from 11 to 112. The mean age was 35.8 years and the known mean followup was 2.2 years (four studies). All studies included both men and women but did not separate out results. Thirty-eight percent of patients were rendered continent with spontaneous voiding (range 0-87 percent). If patients continent with CICS are included, then the mean "cure" rate is 82 percent (range 56-100 percent) and the improvement rate is 90 percent (71-100 percent).

Complications included recurrent UTI (29 patients), persistent mucus formation (11 patients), hourglass stricture at the vesicocecal anastomosis (1 patient), and complications from the artificial sphincter (3 mechanical problems, 1 pump erosion, 1 cuff erosion). The total complication rates were 47 of 87 (54 percent) for the augmentation and 5 of 22 (44 percent) for the artificial sphincter.

#### Bladder Denervation Procedures

Subtrigonal phenol injections (Blackford, Murray, Stephenson, et al., 1984; Ewing, Bultitude, and Shuttleworth, 1982; Nordling, Steven, Meyhoff, et al., 1986; Rosenbaum, Shaw, and Worth, 1990; Wall and Stanton, 1989) and bladder denervation (Alloussi, Loew, Mast, et al., 1984; Diokno, Hollander, and Alderson, 1987; Hodgkinson and Drukker, 1977; Lucas, Thomas, Clarke, et al., 1988; McGuire and Savastano, 1984; Opsomer, Klarskov, Holm-Bentzen, et al., 1984; Rockswald, Chou, and Bradley, 1978; Torring, Petersen, Kelmar, et al., 1988) are not presently recommended because the "cure" rates are low, and therefore the risk-to-benefit ratio is too great.

##### Subtrigonal or transvesical phenol injection

Five series of patients treated with subtrigonal phenol injections were reviewed and combined to include a total of 244 patients (Blackford, Murray, Stephenson, et al., 1984; Ewing, Bultitude, and Shuttleworth, 1982; Nordling, Steven, Meyhoff, et al., 1986; Rosenbaum, Shaw, and Worth, 1990; Wall and Stanton, 1989). "Cure" was not defined in all studies, but a short-term (< 6 months) response was reported in 142 patients. Almost all patients had relapsed by 2 years, however. For the combined series, complications included trigonal ulcer, vesicovaginal fistula, hematuria, vesicoureteral reflux, partial sciatic nerve palsy, obstructive voiding symptoms, and permanent urinary retention. The total complication rate was 12.3 percent.

Of these five studies subjected to meta-analysis, two reported treating both men and women (Nordling, Steven, Meyhoff, et al., 1986; Rosenbaum, Shaw, and Worth, 1990), and the other three included female patients only. Combined analysis of all male subjects revealed that the phenol injection produced no "cure" or improvement. Of the 234 female subjects, 8.6 percent were "cured" and an average of 52.5 percent were "cured" or improved.

Thus, transvesical phenol injection appears to be totally ineffective in "curing" or improving male continence, ineffective in "curing" female incontinence, and only possibly effective in improving female incontinence.

##### Bladder denervation

Eight studies of bladder denervation were reviewed. In three, bladder denervation was used to treat idiopathic DI in patients with no demonstrable neurologic lesions (Alloussi, Loew, Mast, et al., 1984; Diokno, Vinson, and McGillicuddy, 1977; Hodgkinson and Drukker, 1977). Three other studies examined patients with DH from known neurologic problems (McGuire and Savastano, 1984; Rockswald, Chou, and Bradley, 1978; Torring, Peterson, Kelmar, et al., 1988). Two studies included patients in both categories (Lucas, Thomas, Clarke, et al., 1988; Opsomer, Klarskov, Holm-Bentzen, et al., 1984).

The three studies concerning only idiopathic DI included a total of 52 patients (Alloussi, Lowe, Mast, et al., 1984; Diokno, Vinson, and McGillicuddy, 1977; Hodgkinson and Drukker, 1977). Denervation was accomplished by selective sacral rhizotomy, S3 foramen injection, or transvaginal denervation. Only 20 patients had a stated followup period longer than 1 year. Combined analysis of all treated patients revealed an average of 40.4 percent "cured" and an average of 59.4 percent "cured" or improved. The only complication listed was perineal hypoesthesia.

The three studies concerning only true neurologic disease included 34 patients (McGuire and Savastano, 1984; Rockswald, Chou, and Bradley, 1978; Torring, Peterson, Kelmar, et al., 1988). Twenty-three had multiple sclerosis, nine had paraplegia or quadriplegia, and two had cerebral lesions. Denervation was accomplished by selective sacral rhizotomy in 19, sacral rhizotomy in 12, and 2-4 dorsal root ganglionectomy in three. Followup ranged from 2 to 10 years. Combined analysis of all treated patients revealed an average of 47.1 percent "cured" or improved. Complications included one wound infection and two episodes of intra-operative bleeding. The two studies concerning both types of instability were the only studies in which long-term followup (at least 4 years) was reported for all patients after selective sacral rhizotomy (Opsomer, Klarskov, Holm-Bentzen, et al., 1984; Lucas, Thomas, Clarke, et al., 1988). Thirteen patients (50 percent) had either persistent or recurrent incontinence, and six others were dry only with additional treatment with anticholinergics. Thus, the long-term results were not favorable.

### Overflow Incontinence: Bladder Neck or Urethral Obstruction

Symptoms of overflow or incontinence secondary to urethral obstruction can be addressed with a surgical procedure to relieve the obstruction. (Strength of Evidence = B.)

Intermittent catheterization or an indwelling catheter may be considered in patients who are not candidates for surgery and suffer overflow incontinence due to urethral obstruction. (Strength of Evidence= C.)

There is no evidence to support the use of urethral dilation for the treatment of incontinence in women, although it may be useful in the extremely rare cases of primary obstruction. (Strength of Evidence = C.)

Internal urethrotomy is not recommended for treating urethral obstruction in women. (Strength of Evidence = C.)

Overflow incontinence should be ruled out during the basic evaluation. PVR volume can be evaluated by catheterization or by pelvic ultrasound. If overflow incontinence is discovered, its cause -- anatomic obstruction, detrusor weakness, or both -- should be determined.

A patient with a persistently underactive detrusor with or without obstruction is best treated by intermittent catheterization (IC). A patient with an underactive detrusor and outlet obstruction has a significantly lower chance of favorable surgical outcome than a patient with normal detrusor activity. If the patient or caregivers are unable to perform urethral catheterization, other options include indwelling urethral or suprapubic drainage, or supravesical diversion.

If the etiology is anatomic obstruction with an adequately contracting detrusor and the patient has an acceptable level of surgical risk, the best treatment is surgery.

#### The Female Patient

In women, anatomic obstruction can result from prior anti-incontinence surgery or severe pelvic prolapse. For women who have anatomic obstruction after anti-incontinence surgery, two procedures can relieve the obstruction. Obstruction from an endoscopic needle bladder neck suspension can be relieved by cutting one of the suspending sutures. To evaluate the outcome of this procedure, five studies were reviewed (Araki, Takamoto, Hara, et al., 1990; Fowler, 1986; Huland and Bucher, 1984; Mundy, 1983; Vordermark, Brannen, Wettlauffer, et al., 1979). The combined series of 4 studies included 182 patients who had had a needle bladder neck suspension. Ten patients (5 percent) developed obstructive voiding symptoms, which were resolved after one suture was out; only one patient had a recurrence of incontinence.

The other procedure -- urethrolysis (remobilization of the periurethral adhesions) with or without resuspension -- can be used after almost any type of anti-incontinence surgery. Three studies included 41 patients who were classified by symptoms and urodynamic studies and underwent urethrolysis through a transvaginal approach in combination with a repeat endoscopic suspension regardless of the presence or absence of preoperative incontinence McGuire, Letson, and Wang, 1989; Nitti and Raz, 1994; Zimmern, Hadley, Leach, et al., 1987). Seventy-one percent of the patients had improved voiding patterns by urodynamic evaluation, and 80 percent had some improvement in symptoms, with 79 percent of those who were incontinent preoperatively exhibiting resolution of their stress incontinence.

#### The Male Patient

In elderly men, the most common cause of anatomic obstruction is benign prostatic hyperplasia (BPH). The treatment of BPH is multifaceted and is addressed inBenign Prostatic Hyperplasia: Diagnosis and Treatment. Clinical Practice Guideline.

## Other Measures and Supportive Devices

Other measures and supportive devices used in the management of UI include the following:

- Intermittent catheterization.
- Indwelling urethral catheterization.
- Suprapubic catheters.
- External collection systems.
- Penile compression devices.
- Pelvic organ support devices.
- Absorbent pads or garments.

### Intermittent Catheterization

IC is recommended as a supportive measure for patients with spinal cord injury, persistent UI, or chronic urinary retention secondary to underactive or partially obstructed bladder. (Strength of Evidence = B.)

IC has become standard treatment for persons with spinal cord injuries and for patients with other forms of chronic urinary retention due to an underactive or partially obstructed bladder. This procedure can be performed by patients or their caregivers using sterile or clean catheters to provide intermittent routine bladder emptying every 3-6 hours. Long-term use of IC appears preferable to indwelling catheterization in regard to complications such as infections and bladder and renal stones; however, well-designed comparison studies have not been performed ( Webb, Lawson, and Neal, 1990; Warren, 1990). In spinal cord patients, the incidence of bacteriuria is 1-3 percent per IC, and between one and four episodes per 100 days of catheterization using IC four times a day Warren, 1994). Other complications include urethral inflammation, stricture, false passage, hydronephrosis, and epididymitis (Webb, Lawson, and Neal, 1990).

Clean technique for IC is recommended for young, male, neurologically impaired individuals. (Strength of Evidence = B.)

Sterile technique for IC is recommended for elderly patients and patients with compromised immune system. (Strength of Evidence = C.)

IC may be performed as a clean or sterile procedure among young, neurologically impaired individuals. The nonsterile clean approach appears to result in rates of infection lower than those noted with indwelling catheters. Furthermore, the infections that do occur are usually managed without complication provided vesicourethral reflux does not exist, and bladder overdistension and trauma are avoided (Diokno, Sonda, Hollander, et al., 1983; Perkash and Giroux, 1993; Wyndaele and Maes, 1990).

King, Carlson, Mervine, et al. (1992) compared the incidence of urinary tract infection (UTI) using sterile and clean procedures in 46 randomly assigned, hospitalized, young patients with spinal cord injuries. Sterile catheter kits and procedures were utilized during IC of 23 subjects, and the remainder used the clean technique but did use a new sterile catheter every 24 hours. Results showed no statistical differences in symptomatic or asymptomatic infections between the two groups. The investigators recommended the use of a new sterile catheter every 24 hours if the clean procedure is used.

A followup study of clean IC in 50 nonhospitalized male patients with spinal cord injuries (mean age = 46; range = 19-70 years), with a followup period of 3 months to 6.5 years (mean of 22 months), reported that 43 of the 50 subjects (86 percent) developed significant bacteriuria, and 31 genitourinary complications occurred in 21 patients (Perkash and Giroux, 1993). The investigators concluded that clean intermittent catheterization can be a long-term management approach for spinal cord patients; however, this intervention is not without risk of secondary complications. Thus, close monitoring is required so that early and effective treatment can be provided to prevent serious problems. Furthermore, the investigators also noted that maintenance of acceptable intravesical pressures with the use of anticholinergic therapy was important in avoiding serious complications in this group of patients.

The susceptibility of older persons to develop nosocomial infections puts them at higher risk than younger persons for developing bacteriuria and other complications caused by IC. Elderly and other persons with impaired immune systems and atrophic mucosa are also at risk (Terpenning, Allada, and Kauffman, 1989; Warren, 1990). Although the incidence of infection and other complications for elderly patients using sterile versus clean IC is not well established, it appears that sterile IC is the safest method for this high-risk population (Terpenning, Allada, and Kauffman, 1989). Older persons who have the physical and cognitive abilities and who are motivated can be taught to perform IC. A caregiver can also be instructed to perform IC for impaired individuals.

Routine use of long-term suppressive therapy with antibiotics in patients with chronic, clean IC is not recommended. (Strength of Evidence = B.)

In high-risk populations, for example, those with an internal prosthesis or those who are immunosuppressed because of age or disease, the use of antibiotic therapy for asymptomatic bacteriuria must be individually reviewed. (Strength of Evidence = C.)

As a general rule, the use of long-term suppressive therapy with antibiotics in people regularly using clean IC is undesirable because it is associated with the emergence of resistant bacterial strains. It is generally agreed that symptomatic UTI should be treated. In high-risk populations, for example, those with an internal prosthesis or those who are immunosuppressed because of age or disease, the use of antibiotic therapy for asymptomatic bacteriuria must be individually reviewed (Joseph, Jacobson, Strausbaugh, et al., 1991; Wahlquist, McGuire, Greene, et al., 1983). Controlled trials are needed to further evaluate the benefit-risk ratio of these methods of continence management.

### Indwelling Urethral Catheters

Indwelling catheters may be recommended as a supportive measure for patients whose incontinence is caused by obstruction and for whom other interventions are not feasible. Indwelling catheters are recommended for selected incontinent patients who are terminally ill or for patients with pressure ulcers as short-term treatment. (Strength of Evidence = B.)

Indwelling catheters are recommended in severely impaired individuals in whom alternative interventions are not an option and when a patient lives alone and a caregiver is unavailable to provide other supportive measures. (Strength of Evidence = C.)

An indwelling urethral (Foley) catheter is a closed sterile system inserted through the urethra to allow bladder drainage. The use of indwelling catheters should be restricted to persons whose incontinence is caused by urinary tract obstruction that cannot otherwise be treated and for which alternative therapy is not feasible. Examples include acutely ill persons for whom incontinence interferes with necessary monitoring of fluid balance and terminally ill or severely impaired persons for whom bed and clothing changes are painful or disruptive. In situations where the severity of the incontinence and the complexity of the person's care have contributed to skin irritation or pressure ulcers (Stage III or IV), an indwelling catheter may be indicated for short-term therapy until the skin condition resolves.

Studies suggest that approximately 50 percent of nursing home patients are incontinent and that approximately 2-4 percent may require urinary catheterization; however, the actual prevalence of use of indwelling catheters measured in several nursing homes ranges from 6 to 28 percent (Ouslander, Kane, and Abrass, 1982; Warren, Steinberg, Hebel, et al., 1989). Indwelling catheter use in the homebound patient is common and requires supervision by a registered nurse and additional personal hygiene care by paraprofessionals. The use of these devices in homebound individuals increases the cost of caring for these persons.

Long-term use of indwelling catheters is a significant cause of bacteriuria and UTI. Bacteriuria, which may be caused by encrustation formation of mineral and bacteria complexes, develops in most persons within 2-4 weeks after catheter insertion (Bjork, Pelletier, and Tight, 1984; Cox, Hukins, and Sutton, 1989; Tenney and Warren, 1988; Warren, Muncie, and Hall-Craggs, 1988). Cases of sepsis and death from severe UTI have been reported. In a nursing home population, mortality was three times higher in those with indwelling catheters than in noncatheterized patients, with significantly increased mortality in catheterized females (Kunin, Chin, and Chambers, 1987a; Kunin, Chin, and Chambers, 1987b). Other complications associated with indwelling catheters include obstruction secondary to encrustation, leakage, unprescribed removal, pain, bladder spasms, urethral erosion, stones, epididymitis, urethritis, periurethral abscess, chronic renal inflammatory changes, fistula formation, hematuria, and urinary leakage (Kunin, 1989; Warren, Muncie, and Hall-Craggs, 1988). Patients who are being managed with indwelling catheters over a long period of time should have their bladders evaluated by urologists on a routine basis.

Management of indwelling catheters varies. The usual practice is to change indwelling catheters every 30 days, but no data are available on the optimal frequency of catheter changes. Patients found to have encrustations and blockage might do better if their catheters were changed more frequently than every 30 days Kunin, Chin, and Chambers, 1987a). If the patient has symptomatic UTI, the entire catheter and system must be changed and a new urine culture obtained when the new catheter is inserted (Grahn, Norman, White, et al., 1985; Rubin, Berger, Zodda, et al., 1980). No studies have identified an ideal catheter size, balloon size, or type of indwelling catheter, although most experts agree that the standard catheter size is 14FR, 16FR, or 18FR with a 5-cc balloon filled with 10 cc of sterile water. There is evidence to refute the practice of catheter irrigation and clamping before removal; in addition, disinfection of urinary drainage bags is ineffective in preventing infection (Thompson, Haley, Searcy, et al., 1984). Routine bladder irrigation of catheters not only is ineffective in eradicating bacteriuria but also may further disrupt the already damaged bladder epithelium, predisposing the patient to further infection (Elliott, Gopal Rao, Reid, et al., 1987; Ruwaldt, 1983). Routine irrigation is not recommended if obstruction occurs. In patients with frequent obstruction, the system should be changed and other types of catheters or alternative management should be considered. A person with an indwelling catheter must be reassessed periodically to determine whether a voiding trial or bladder retraining program might be effective in eliminating the need for the catheter or whether surgical risk might now be improved such that a surgical procedure could be performed to relieve obstruction.

It is not known which type of catheter (e.g., silicone, latex, Teflon) is best. Specific risks are difficult to assess because studies generally do not report the type or brand of catheter used. The development of silver-coated, antimicrobial, lubricous-coated, and female catheters may decrease the formation of encrustation and other complications; however, further research on these products is needed to determine their effectiveness (Blacklock, 1986; Brocklehurst, Hickey, Davies, et al., 1988; Johnson, Roberts, Olsen, et al., 1990; Kunin and Finkelberg, 1971; Liedberg and Lundeberg, 1990; Liedberg, Lundeberg, and Ekman, 1990).

### Suprapubic Catheters

Suprapubic catheters are for short-term use following gynecologic, urologic, and other surgery, or as an alternative to long-term catheter use. Suprapubic catheterization is contraindicated as a long-term management option in persons with chronic unstable bladder (DI, DH) and ISD. (Strength of Evidence = B.)

Suprapubic catheterization involves percutaneous or surgical introduction of a catheter into the bladder through the anterior abdominal wall. Indications include short-term use following gynecologic, urologic, and other types of surgery or as an alternative to long-term catheter use in men and in women with urethral closure. Suprapubic catheters are contraindicated in persons with chronic unstable bladder (DI, DH) or ISD. Stower, Massey, and Feneley (1989) treated 50 patients with diagnoses of neurogenic bladder with suprapubic catheterization and urethral closure. Patients in this series had either severe neurologic disease or pressure ulcers, or had refused an ileal conduit. Complications included leakage around the catheter (17 percent), bladder stone formation (21 percent), symptomatic UTI (90 percent), and recurrent blocked catheter (10 percent).

Barnes, Shaw, Timoney, et al. (1993) studied 40 outpatients (23 women, 17 men) with a mean age of 45 years in whom suprapubic catheters were used to manage UI over a 2-year period. Thirty-five of the subjects had suffered traumatic spinal cord injury, and five had spinal cord lesions of nontraumatic origin. All had failed or declined to use IC to empty their bladders. Catheter-related problems were common, and only five patients had experienced no problems since insertion. The researchers reported good results utilizing size 14-16 French catheters, anticholinergic drug therapy, and daily clamping of the catheter. Only patients not using the medication and daily clamping regimen experienced reflux and decrease in bladder capacity. Leakage from the urethra and blocking of the catheter was reported for five patients. No discussion of problems with bacteriuria was presented. Immediate complications included cellulitis, hematoma, and bowel injury of 32 patients who expressed an opinion; 27 were satisfied with this form of bladder management. Long-term complications were similar to those associated with the use of indwelling catheters (Feneley, 1983; Stower, Massey, and Feneley, 1989).

Further studies are needed on the use of suprapubic catheterization for long-term management of UI. In the absence of data, panel consensus is that a suprapubic catheter is preferable to an indwelling catheter in the patient who requires chronic bladder drainage and for whom no other alternative therapy is possible, because it eliminates urethral complications. However, management of suprapubic catheters presents potential problems such as uncontrolled urine leakage, skin erosion, and hematoma, and problems with catheter reinsertion. Long-term medical management of suprapubic catheterization may also be problematic if health care providers lack knowledge and expertise and if the homebound patient lacks quick access to medical care if a problem arises. Suprapubic catheterization may be preferable to urethral catheters; however, additional studies are needed to better describe the benefits and risks of this treatment.

### External Collection Systems

External collection systems are recommended for incontinent men and women who have adequate bladder emptying, who have intact genital skin, and in whom other therapies have failed or are not appropriate. (Strength of Evidence = C.)

External (condom) systems for men are catheters or devices made from latex rubber, polyvinyl, or silicone that are secured on the shaft of the penis by a double-sided adhesive, latex inflatable cuff, jockey's type strap, or foam strap, and connected to urine collecting bags by a tube. Condom catheters should not be used in patients with chronic obstruction. Frail, elderly males with cognitive impairment, who are considered candidates for condom catheter use, should be evaluated for symptomatic UTI, urinary retention, and upper tract damage before using these devices.

Patients and their caregivers should be carefully instructed in the proper application of external catheters and taught to check for possible complications. Although external catheters are preferable to indwelling catheters, they are also associated with UTI Johnson, 1983; Ouslander, Greengold, and Chen, 1987b). Mechanical irritation and penile constriction may also occur from the friction caused by an external catheter (Jayachandran, Mooppan, and Kim, 1985). Therefore, the penis should be inspected daily, and careful attention must be given to avoid contact dermatitis, maceration of the penis, ischemia, and penile obstruction. Most complications result from improper and prolonged use of these devices. Also, persons with sensory loss secondary to neuropathy are unable to appreciate the potential for trauma to the area associated with improper use of the condom device (Jayachandran, Mooppan, and Kim, 1985).

Female external urine-collecting systems are available, but little research on their use and efficacy is available. External urine-collecting devices for women differ in their use of a vaginal locator, adhesive, suction, support belt, potential length of wear, and mobility with use (Pieper, Cleland, Johnson, et al., 1989). Johnson, O'Reilly, and Warren 1989) studied 63 applications of an external urine-collection device on incontinent women in a nursing home. The device was a flexible, plastic pouch that funneled urine through a connecting tube into a bedside collector. This device was allowed to remain in situ for a maximum of 48 hours. Only 14 percent of the devices required premature replacement because of unacceptable leakage. The primary adverse reaction was mild erythema. However, removal of the device was required for two patients with severe irritation and one patient with periurethral edema. Johnson, Muncie, O'Reilly, et al., (1990 ) studied the use of external collecting devices in 26 women (mean age 79.8) residing in a rehabilitation center. Of 2,461 external device applications, almost 80 percent were adherent and leak free at 24 hours, and almost half were still adherent and leak free at 48 hours. There was no difference in mean wear time among 13 patients who were strictly bedridden; however, device leakage increased when a transfer (bed to chair) took place compared with no transfer. Periurethral erythema was observed in 1.6 percent of patients after removal of the device. The incidence of episodes of bacteriuria was 3.1 episodes per 100 days of external device use. Reported adverse reactions to the use of these devices include periurethral erythema and perineal itching (Johnson, Muncie, O'Reilly, et al., 1990; Johnson, O'Reilly, and Warren, 1989).

### Penile Compression Devices

Penile compression devices are known to be used in clinical practice in the treatment of UI. No scientific literature was found to support the use of these devices. The panel recognizes the temporary use of penile compression devices in males in selected circumstances under the supervision of a health care provider. (Strength of Evidence = C.)

Mechanical devices for males, such as penile clamps, are reserved for temporary use in patients with ISD. Clamps must be removed at 3-hour intervals to empty the bladder. Several types are available; however, complications such as penile and urethral erosion, penile edema, pain, and obstruction can occur if clamps are improperly used.

### Pelvic Organ Support Devices

Pessaries are recommended for women who have symptomatic pelvic organ prolapse. (Strength of Evidence = C.)

Data are not available to recommend or discourage the use of pessaries for the treatment of UI in women. (Strength of Evidence = C.)

Pessaries are devices made of rubber or silicone materials, or both, designed to reduce pelvic prolapse temporarily and alleviate symptoms of pelvic organ prolapse in females with and without incontinence. Pessaries are available in various sizes and shapes depending on the type and severity of prolapse and the integrity of the perivaginal muscles. Pessaries are recommended for women with symptomatic pelvic organ prolapse in two circumstances: (1) as a temporary measure for women awaiting surgical correction and (2) for treatment of women who are either unable, for medical reasons, or are unwilling to undergo correction of the prolapse. Use of the Smith Hodge vaginal pessary is reported to be an effective preoperative device for predicting the relative success of incontinence surgery for SUI (Bhatia and Bergman, 1985b). Objective evidence regarding their effectiveness in reducing UI has not been reported. Use of pessaries requires fitting and frequent and regular monitoring by trained health care providers. Complications can result when the pessary is misused or neglected and can include ulceration of the vagina and rectovaginal and vesicovaginal fistula Goldstein, Wise, and Tancer, 1990). These devices should not be used in women with vaginal prolapse, in those who have vaginitis, or in those who cannot remove or insert the device without routine access to a health care provider.

A new vaginal device specifically designed to support the bladder neck in women with stress incontinence may hold promise for those who have sufficient manual dexterity and can learn to insert and remove the device. Davila and Osterman (1994) reported that of 30 physically active women studied, 25 were dry with the device. The mean number of weekly incontinent episodes decreased from 10 per week before treatment to 3 per week with the device in place (P = 0.009).

### Absorbent Products

Absorbent products are recommended during evaluation, as an adjunct to other therapy, and for long-term care of patients with chronic, intractable urinary incontinence. (Strength of Evidence = C.)

Absorbent products and garments include the following:

- Shields, which are small absorbent perineal inserts.
- Guards, close-fitting products designed for light incontinence.
- Undergarments, which consist of full-length pads usually held in place by waist straps.
- Combination pad - pant systems.
- Adult diaper garments.
- Bed pads.

Absorbent pads and garments, either disposable or reusable, are widely used by persons with UI. Many community-dwelling persons use these products because of the protection they provide and because they can avoid seeking professional help for their problem. Others resort to pads because they have been dismissed rather than treated when seeking help for UI. From their perspective, absorbent products are a useful and rational way to manage the problem.

The widespread use of these products is reflected in the growth of the market of disposable pads and adult diapers from $99 million in 1972, to $173 million in 1982, to $496 million in 1987. Costs vary depending on the product and can be excessive for those on limited incomes. In 1987, these costs contributed to approximately half of the direct care costs for incontinence among residents in nursing homes (Sowell, Schnelle, Hu, et al., 1987). Although the quality and materials used in these products vary widely, little objective evaluation of disposable products has been conducted. Studies comparing cloth protective garments with disposable products have been conducted (Hu, Kaltreider, and Igou, 1990), but research comparing effectiveness and adverse effects of the various disposable products is lacking. Absorbent products are helpful during assessment and treatment of urinary incontinence. They also have a place as an adjunct to behavioral and other therapies, and in the care of persons with intractable incontinence. However, these products should not be used in place of therapeutic interventions to decrease or eliminate UI. Early dependency on absorbent pads may be a deterrent to continence, giving the wearer a sense of security and acceptance of the condition that removes the motivation to seek evaluation and treatment (Starer and Lobow, 1985). In addition, improper use of absorbent products may contribute to skin breakdown and UTI. Thus, appropriate use, meticulous care, and frequent garment changes are needed.

The following factors should be considered when absorbent products are used:

- Functional disability of the patient.
- Type and severity of incontinence.
- Gender.
- Availability of caregivers.
- Failure with previous treatment programs.
- Patient preference.
- Optimal product for individual patient.
- Skin integrity.
- Comorbidity.
- Incidence of vaginitis and bacteriuria.
- Quality of the product.
- Cost of the product.

In addition, it is recommended that the absorbent product industry standardize terminology and describe content and product performance (e.g., absorbency) to facilitate patient selection National Kidney and Urologic Diseases Advisory Board, 1994). Research needs to be conducted to compare various factors of available products. Such studies would help health care providers make recommendations based on fact and will ultimately lead to the development of better products.