# Identifying and Evaluating Urinary Incontinence

## Symptoms and Subtypes

UI can be caused by anatomic, physiologic, and pathologic (genitourinary) factors affecting the urinary tract, as well as external (nongenitourinary) factors. Multiple and interacting factors often contribute to UI development, especially in frail, older patients (Ouslander and Bruskewitz, 1989 ). In such patients, the diagnostic evaluation must be comprehensive, focusing not only on the lower urinary tract but also on the patient's general medical and functional status.

Several conditions that cause or contribute to UI are potentially reversible (see Table 2). Management of one or more of these conditions can sometimes lead to the resolution of the UI. This potentially reversible type of UI has been referred to as transient incontinence. In other patients, treatment of these conditions will reduce the severity of UI but will not totally resolve it. Several different nosologies have been used to classify the various types of UI. The classification of subtypes of UI used here is based on symptoms so as to facilitate use of this guideline by primary health care providers. Often, classifications used by specialists incorporate primarily pathophysiologic characteristics.

Table 2. Identification and management of reversible conditions that cause or contribute to urinary incontinence

Condition | | | Management
Conditions affecting the lower urinary tract
Urinary tract infection (symptomatic with frequency, urgency,dysuria, etc.) | | | Antimicrobial therapy
Atrophic vaginitis/urethritis | | | Oral or topical estrogen (see Chapter 3 section on Pharmacologic Treatment)
Pregnancy/vaginal delivery/episiotomy | | | Behavioral intervention. Avoid surgical therapy postpartum as condition may be self-limiting
Postprostatectomy | | | Behavioral intervention. Avoid surgical therapy until clear condition will not resolve.
Stool impaction | | | Disimpaction; appropriate use of stool softeners, bulk-forming agents, and laxatives if necessary; implement high fiber intake, adequate mobility and fluid intake
Drug side effects [a]
- Diuretics:; - causing polyuria, frequency, and urgency; - Caffeine:; - causing aggravation or precipitation of UI; - Anticholinergic agents:; - causing urinary retention, overflow incontinence, impaction; - Psychotropics:; - - Antidepressants: causing anticholinergic actions, sedation; - - Antipsychotics: causing anticholinergic actions, sedation, rigidity, and immobility; - - Sedatives/hypnotics/CNS depressants: causing sedation, delirium, immobility, muscle relaxation; - Narcotic analgesics:; - causing urinary retention, fecal impaction, sedation, delirium; - Alpha-adrenergic blockers:; - causing urethral relaxation; - Alpha-adrenergic agonists:; - causing urinary retention (present in many cold and diet over-the-counter (OTC) preparations); - Beta-adrenergic agonists:; - causing urinary retention; - Calcium channel blockers:; - causing urinary retention; - Alcohol:; - causing polyuria, frequency, urgency, sedation, delirium, immobility | | | With all medications discontinue or change therapy, as clinically possible. Dosage reduction or modification (e.g., flexible scheduling of rapid- acting diuretics) may also help.
Increased urine production
Metabolic (hyperglycemia, hypercalcemia) | | | Better control of diabetes mellitus. Therapy for hypercalcemia depends on underlying cause.
Excess fluid intake | | | Reduction in intake of diuretic fluids (e.g., caffeinated beverages)
Volume overload
Venous insufficiency with edema | | | Support stocking Leg elevation Sodium restriction Diuretic therapy
Congestive heart failure | | | Medical therapy
Impaired ability or willingness to reach a toilet
Delirium | | | Diagnosis and treatment of underlying cause(s) of acute confusional state
Chronic illness, injury, or restraint that interferes with mobility | | | Regular toileting Use of toilet substitutes Environmental alterations (e.g., bedside commode, urinal)
Psychological | | | Remove restraints if possible. Appropriate pharmacologic and/or nonpharmacologic treatment

a Many side effects are seen with over-the-counter (OTC) drugs, the use of which may not be reported by some patients.

### Urge Incontinence

The symptom of urge incontinence is the involuntary loss of urine associated with a strong desire to void (urgency). Urge incontinence is usually, but not always, associated with the urodynamic finding of involuntary detrusor contractions, referred to as detrusor instability (DI). Although DI can be associated with neurologic disorders, it also occurs in individuals who appear to be neurologically normal. The uninhibited bladder contractions associated with DI can cause UI with and without symptoms of urgency; it can also cause symptoms of urgency without concomitant incontinence (Fantl, Wyman, McClish, et al., 1991). When a causative neurologic lesion is established, the DI is called detrusor hyperreflexia (DH) (Abrams, Blaivas, Stanton, et al., 1988). A common neurologic disorder associated with DH is stroke. In patients with suprasacral spinal cord lesions and multiple sclerosis, DH is commonly accompanied by detrusor sphincter dyssynergia (DSD) (inappropriate contraction of the external sphincter with detrusor contraction). This can result in the development of urinary retention, vesicoureteral reflux, and subsequent renal damage (McGuire, Woodside, Borden, et al., 1981).

Another urodynamic diagnosis associated with the symptom of urge incontinence in frail, elderly patients is detrusor hyperactivity with impaired bladder contractility (DHIC) (Resnick and Yalla, 1985). Patients with DHIC have involuntary detrusor contractions, yet must strain to empty their bladders either incompletely or completely. Clinically, patients with DHIC generally have symptoms of urge incontinence and an elevated postvoid residual (PVR) volume, but they may also have symptoms of obstruction, stress incontinence, or overflow incontinence. DHIC must be distinguished from other types of UI because it can mimic them, resulting in inappropriate diagnosis and treatment.

### Stress Incontinence

The symptom of stress urinary incontinence (SUI) presents clinically as the involuntary loss of urine during coughing, sneezing, laughing, or other physical activities that increase intra-abdominal pressure. SUI is defined as urine loss coincident with an increase in intra-abdominal pressure, in the absence of a detrusor contraction or an overdistended bladder. The most common cause of SUI in women is urethral hypermobility, or significant displacement of the urethra and bladder neck during exertion when intra-abdominal pressure is raised.

SUI may also be caused by an intrinsic urethral sphincter deficiency (ISD), which may be due to congenital sphincter weakness in patients with myelomeningocele, epispadias, or pelvic denervation, or may be acquired after prostatectomy, trauma, radiation therapy, or a sacral cord lesion. In women, ISD is commonly associated with multiple incontinence surgical procedures, as well as with hypoestrogenism, aging, or both. In this condition, the urethral sphincter is unable to generate enough resistance to retain urine in the bladder, especially during stress maneuvers (Blaivas, 1985; Staskin, Zimmern, Hadley, et al., 1985). Patients with ISD often leak continuously or with minimal exertion. In some patients, stress incontinence results from coexisting ISD and hypermobility of the urethra and bladder neck.

### Mixed Incontinence

It is not unusual for patients to present with a combination of urge and stress incontinence (Fantl, Wyman, McClish, et al., 1990; Ouslander, Hepps, Raz, et al., 1986). When both symptoms are present, the incontinence is called mixed UI. Mixed UI is common in women, especially older women. Often, however, one symptom (urge or stress) is more bothersome to the patient than the other. Identifying the most bothersome symptom is important in targeting diagnostic and therapeutic interventions.

### Overflow Incontinence

Involuntary loss of urine associated with overdistension of the bladder is termed overflow incontinence. This type of incontinence may have a variety of presentations, including frequent or constant dribbling, or urge or stress incontinence symptoms. Overflow UI may be caused by an underactive or acontractile detrusor, or to bladder outlet or urethral obstruction leading to overdistension and overflow. The bladder may be underactive or acontractile secondary to drugs, neurologic conditions such as diabetic neuropathy, low spinal cord injury, or radical pelvic surgery that interrupts the motor innervation of the detrusor muscle. The detrusor muscle may also be underactive from idiopathic causes.

In men, overflow incontinence associated with obstruction is commonly caused by prostatic hyperplasia and, less frequently, prostatic carcinoma or urethral stricture. Although an outlet obstruction is rare in women, it can occur as a complication of an anti-incontinence operation and because of severe pelvic organ prolapse, in which the organ involved protrudes to or beyond the vaginal orifice (e.g., prolapsing cystocele, uterine prolapse). In patients with suprasacral spinal cord injury or multiple sclerosis, DSD can cause obstruction when the external sphincter muscle inappropriately and involuntarily contracts rather than relaxes at the same time the detrusor contracts (Blaivas, 1985).

### Other Causes and Types

#### Functional Incontinence

Urine loss may be caused by factors outside the lower urinary tract such as chronic impairment of physical or cognitive functioning, or both, a condition commonly termed "functional incontinence" Williams and Pannill, 1982). This diagnosis should be one of exclusion, however, because some immobile and cognitively impaired individuals have other types and causes of UI that may respond to specific therapies (Skelly and Flint, 1995). For example, most nursing home residents have not only functional limitations that interfere with their ability to toilet but also urge UI with detrusor instability or DH. In addition, UI can often be improved or "cured" by improving the patient's functional status, treating other medical conditions, discontinuing certain types of medication, adjusting the hydration status, reducing environmental barriers, or all of the above -- even if a lower urinary tract abnormality is present.

#### Unconscious or Reflex Incontinence

Urine loss may also occur without any warning or sensory awareness such as in paraplegics and some patients without overt neurologic dysfunction. This condition, which also has been termed unconscious incontinence, presents as either postmicturitional or constant (continuous) dribbling. Extraurethral UI (i.e., fistulas), UI in children, and neuropathic conditions are not specifically addressed in this guideline.

Another urodynamic finding that may be associated with UI is decreased bladder compliance. This abnormal bladder condition may result from radiation cystitis, inflammatory bladder conditions such as chemical cystitis or interstitial cystitis, and some neurologic bladder disorders such as those that occur following radical pelvic surgery and in myelomeningocele. Many of the patients with a nonneurogenic etiology for their decreased bladder compliance (e.g., chemical or radiation cystitis) have severe urgency associated with bladder hypersensitivity and with no demonstrable DI. This is termed "sensory urgency." Both loss of bladder wall elasticity and lack of bladder accommodation produce a steep rise in intravesical pressure during bladder filling without detrusor contraction. In patients in whom the urethral sphincter mechanism may already be compromised by the condition that produced the inelastic bladder (e.g., radiation, neurologic dysfunction), the abnormal increase in bladder pressure may overcome the urethral pressure and produce UI. A major concern in patients with a poorly compliant bladder, especially those who are neurologically impaired, is the development of vesicoureteral reflux and hydronephrosis.

## Identifying Urinary Incontinence

Because many people with UI delay or do not seek professional help (Herzog, Fultz, Normolle, et al., 1989; Norton, MacDonald, Sedgwick, et al., 1988), primary health care providers should question their patients regularly to identify UI. Open-ended requests such as "Tell me about the problems you are having with your bladder" and "Tell me about the trouble you are having holding your urine (water)" are a useful initial approach. If the patient responds negatively, more specific questions such as "How often do you lose urine when you don't want to?" and "How often do you wear a pad or other protective device to collect your urine?" may help identify UI. In licensed nursing facilities, assessment of continence status using the Minimum Data Set (MDS) is required within 14 days of admission and every 3 months thereafter (Morris, Hawes, Murphy, et al., 1990).

If UI is identified by questioning, detecting an odor, observing wetness, or by a patient complaint, and represents a problem for the patient or caregiver, evaluation should be undertaken as described below.

## General Principles of Diagnostic Evaluation

Health care providers are encouraged to be knowledgeable about and initiate the basic evaluation of patients with UI. (Strength of Evidence = C.)

When UI is a problem for the patient or caregiver, the patient should undergo a basic evaluation by a health care provider. UI has traditionally been evaluated by specialists, including gynecologists and urologists, and in some rehabilitation settings, by physiatrists. Given the high prevalence of UI in the general population, however, limiting UI evaluation and management to these specialists is not feasible. The panel encourages primary health care providers, such as family physicians, general internists, geriatricians, nurse practitioners and specialists, and physician assistants, to be knowledgeable about and able to initiate the basic evaluation of UI.

## Basic Evaluation

All patients with UI should undergo a basic evaluation that includes a history, physical examination, measurement of postvoid residual volume, and urinalysis. (Strength of Evidence = B.)

Risk factors that are associated with UI should be identified and attempts made to modify them. (Strength of Evidence = B.)

### Purpose

UI is a symptom and not a condition in itself. Thus, the purposes of the basic evaluation are to

1. Confirm the presence of UI.
2. Identify conditions, including potentially reversible ones (see Table 2), that may be contributing to the UI.
3. Identify patients who require further evaluation before any therapeutic interventions are attempted and patients who may receive initial treatment without further testing.
4. Identify a presumptive diagnosis, if possible.

### Components

The basic evaluation should include a history, physical examination, estimation of PVR volume, and urinalysis. The basic evaluation may not be appropriate for every patient, and every health care provider may not have the background to complete this assessment for some patients. At any time during the basic evaluation, the health care provider may refer the patient for further evaluation by a specialist.

#### History

The history should include (1) a focused medical, neurologic, and genitourinary history that includes an assessment of risk factors (see Table 1) and a review of medications (including nonprescription medications) and (2) a detailed exploration of the symptoms of the UI and associated symptoms and factors, including

- Duration and characteristics of UI (stress, urge, dribbling, others).
- Most bothersome symptom(s) to the patient (which may be especially important in guiding therapy and determining response).
- Frequency, timing, and amount of continent voids and incontinent episodes.
- Precipitants of incontinence (e.g., situational antecedents, cough, certain types of exercises, surgery, injury, previous pelvic radiation therapy, trauma, new onset of diseases, new medications).
- Other lower urinary tract symptoms (e.g., nocturia, dysuria, hesitancy, poor or interrupted stream, straining, hematuria, suprapubic or perineal pain).
- Fluid intake pattern, including caffeine-containing or other diuretic fluids.
- Alterations in bowel habits or sexual function.
- Previous treatments and their effects on UI.
- Amount and types of pads, briefs, and protective devices.
- Expectations for outcomes of treatment.
- A bladder record.
- A mental status evaluation and assessment of mobility, living environment, and social factors, especially in elderly patients.

Bladder records are helpful supplements to the history in many patients (Diokno, Wells, and Brink, 1987; Larson and Victor, 1992; Wyman, Choi, Harkins, et al., 1988). These written records are used to determine the frequency, timing, and amount of voiding, as well as other factors associated with UI. Such a record can be kept by the patient or a caregiver for a few days before the basic evaluation. The record may provide clues about the underlying cause of UI, as well as information on fluid intake and voiding patterns that may be helpful for behavioral interventions, and can serve as a baseline to gauge severity and treatment efficacy (see sample records, Attachments B and C.

A mental status examination should be performed when appropriate. Assessment of mobility and living environment is also especially important in certain individuals. Questions should be asked about access to toilets or toilet substitutes, and about social factors such as living arrangements, social contacts, or caregiver involvement (Williams and Gaylord, 1990).

#### Physical Examination

The physical examination should include the following:

- General examination if indicated to detect conditions such as edema that may contribute to nocturia and nocturnal UI; to detect neurologic abnormalities that may suggest multiple sclerosis, stroke, spinal cord compression, or other neurologic conditions; and to assess mobility, cognition, and manual dexterity related to toileting skills among frail and functionally impaired patients Williams and Gaylord, 1990).
- Abdominal examination to check for diastasis rectii, organomegaly, masses, peritonitis, fluid collections, and so on. Abnormality of abdominal contents may influence intraabdominal pressure and detrusor physiology.
- Rectal examination to test for perineal sensation, sphincter tone (both resting and active), fecal impaction, or rectal mass, and to evaluate the consistency and contour of the prostate in men. The size of the prostate on digital examination does not exclude or imply obstruction and is usually helpful only for the surgeon in determining the surgical approach if an operation is contemplated.
- Genital examination in men to evaluate skin condition and detect abnormalities of the foreskin, glans penis, and perineal skin.
- Pelvic examination in women to assess perineal skin condition, genital atrophy, pelvic organ prolapse (cystocele, rectocele, uterine prolapse), pelvic mass, paravaginal muscle tone, or other abnormalities. Palpation of the anterior vaginal wall and urethra may elicit urethral discharge or tenderness that suggests a urethral diverticulum, carcinoma, or inflammatory condition of the urethra. Pelvic organ prolapse may not relate to urinary symptoms, especially in the elderly (Ouslander, Hepps, Raz, et al., 1986).
- Direct observation of urine loss using the cough stress test. Observation of urine loss can be performed by having the individual cough vigorously while the examiner observes for urine loss from the urethra. Optimally, testing should be done when the patient's bladder is full but before the patient has a precipitant urge to void Kadar, 1988). In women who are being evaluated for specific treatments for stress incontinence, this test is important for objective demonstration of urine loss and identification of provoking factors. In other patients, particularly those with physical or cognitive impairment, direct observation may be difficult to carry out, and this documentation may not be critical in determining initial treatment of incontinence. If an instantaneous leakage occurs with cough, then SUI is likely; if leakage is delayed or persists after the cough, DI should be suspected. If the test is initially performed in the lithotomy position and no leakage is observed, the test should be repeated in the upright position (Kadar, 1988). If bladder filling is needed to perform stress testing, it may be conveniently performed in conjunction with the catheterization method of measurement of PVR volume.

#### Estimation of PVR Volume

Accurate measurement of PVR can be accomplished either by catheterization or by pelvic ultrasound (Coombes and Millard, 1994; Haylen, Frazer, and MacDonald, 1989; Ireton, Krieger, Cardenas, et al., 1990). Some health care providers may use abdominal palpation or bimanual pelvic examination to suspect elevated PVR; however, the exact amount of volume or confirmation usually requires other methods (catheterization, ultrasound) (Norton, Peattie, and Stanton, 1989).

Before PVR is measured, the patient should void in the most comfortable and private environment possible. Voiding can be observed at this time to detect signs of hesitancy, straining, or slow or interrupted stream, which may indicate urethral obstruction, a bladder contractility problem, or both.

Measurement of PVR volume is generally done within a few minutes after voiding by catheterizing the patient or by pelvic ultrasound. Review of the literature failed to indicate a specific maximum PVR volume considered normal, nor is there any documentation of the minimal PVR considered abnormal. In general, PVRs of less than 50 mL are considered adequate bladder emptying. Repetitive PVRs ranging from 100 to 200 or higher are considered inadequate emptying. Clinical judgment must be exercised and all other clinical information included in interpreting the significance of PVR volume, especially in the intermediate range of 50-199 mL.

The PVR urine may be influenced by such factors as the volume voided before PVR measurement, whether the patient is "ready" to void or strains to void, the efforts made to drain the bladder completely, and the environment or clinical setting. Because PVR volume may vary, one measurement of PVR may not be sufficient and repeated measurements may be of value in some patients.

Urethral catheterization in men with prostate obstruction may cause urinary tract infection. Therefore, catheterization in men should be performed only with clear indication and by a health care provider who is prepared to manage abnormal findings.

An alternative to catheterization is the use of pelvic ultrasound. Portable ultrasound devices that estimate PVR with reasonable accuracy are now available (Ireton, Krieger, Cardenas, et al., 1990; Ouslander, Simmons, Tuico, et al., 1994; Topper, Holliday, and Fernie, 1993).

#### Urinalysis

This test is used to detect conditions that are associated with or contributing to UI such as hematuria (suggestive of infection, cancer, or stone), glucosuria (which may cause polyuria and contribute to UI symptoms), pyuria, and bacteriuria, as well as glycosuria and proteinuria. If catheterization is performed for PVR measurement, a sample of the residual urine can be used for the urinalysis and microscopic examination. Careful cleaning of the glans penis in men and the periurethral area in women with an antiseptic solution allows collection of a spontaneously voided specimen that accurately reflects bladder urine.

Dipstick methods are available to detect bacteriuria and pyuria. The diagnostic accuracy of these methods varies considerably among methods and different patient populations (Lachs, Nachamkin, Edelstein, et al., 1992). Therefore, urine cultures should be obtained in incontinent patients when dipstick tests indicate infection or when symptoms suggest infection.

Among chronically incontinent nursing home residents, eradication of bacteriuria (with or without pyuria) has no effect on morbidity, mortality, or the severity of UI (Boscia, Kobasa, Abrutyn, et al., 1986). Thus, unless UI is of recent onset, has recently worsened, or is accompanied by other symptoms of infection (e.g., dysuria, hematuria, fever, sudden decline in mental or physical functioning), bacteriuria (with or without pyuria) does not need to be treated in this patient population. Among noninstitutionalized patients, the relationship of bacteriuria (with or without pyuria) to UI is unclear. Further research is needed to clarify this relationship. Until such data are available, infection should be treated when the incontinent patient is initially evaluated and the effect observed before further diagnostic or therapeutic interventions are undertaken (Ouslander, 1989).

#### Supplementary Assessments

The use of blood tests (BUN, creatinine, glucose, and calcium) and urine cytology in the assessment of the incontinent patient was also evaluated.

Blood testing (BUN, creatinine, glucose, and calcium) is recommended if compromised renal function is suspected or if polyuria (in the absence of diuretics) is present. (Strength of Evidence = C.)

Blood tests that may be helpful in the basic evaluation of the incontinent patient include creatinine levels in patients suspected of having obstruction, noncompliant bladders, or urinary retention. However, normal creatinine levels do not rule out hydronephrosis. Patients with polyuria in the absence of diuretic agents should be evaluated for excess intake (diabetes insipidus), hyperglycemia, and hypercalcemia if indicated.

Urine cytology is not recommended in the routine evaluation of the incontinent patient. (Strength of Evidence = B.)

There is no evidence in the literature to support urine cytology testing in patients with UI. Individuals with incontinence are at no higher risk of bladder cancer than the continent population Mohr, Offord, Owen, et al., 1986 ). Urine cytology is a poor screening test for bladder cancer, with sensitivities ranging from approximately 20-70 percent (Curling, Broome, and Gendry, 1986; Murphy, 1990; Rife, Farrow, and Utz, 1979). Patients with hematuria (2-5 RBC/hpf) or acute onset of irritative voiding symptoms in the absence of urinary tract infection (UTI) require cystoscopy and cytology to exclude bladder neoplasm (Utz and Zincke, 1974).

## Further Evaluation

After the basic evaluation, treatment for the presumed type of urinary incontinence should be initiated unless there is an indication for further evaluation. (Strength of Evidence = B.)

After the basic evaluation, all incontinent patients in whom transient (reversible) causes of UI have been detected should be treated appropriately (see Table 2). If UI persists after the transient causes are identified and treated, further evaluation may be helpful before therapy is initiated.

Examples of patients who may not need further evaluation before initiating treatment follow:

- Patients with SUI, normal PVR volume, and no complicating features.
- Patients with urge UI, normal PVR volume, and no complicating features.
- Women with mixed urge-stress UI with normal PVR volume and no complicating features for whom behavioral or pharmacologic therapy, or both, is preferred.

Initial management options for these patients are outlined in Table 3.

Patients requiring further evaluation include those who meet any of the criteria in Table 4. Because of their general medical condition, some of these patients may not be appropriate for further evaluation, particularly if it is not desired by the patient or feasible.

Table 3. Management options after basic evaluation

Type of UI | Characteristics | | Management options
Urge | Detrusor instability With normal PVR, no complicating factors | | Behavioral techniques:; - -Bladder training; - -Pelvic muscle rehabilitation; - -Other (e.g., fluid management); Pharmacologic interventions:; - -Anticholinergic medications, tricyclic antidepressants as alternative
Stress | With normal PVR, no complicating factors | | Behavioral techniques:; - -Pelvic muscle rehabilitation; - -Bladder training; Pharmacologic techniques:; - -Alpha-adrenergic medications or tricyclic antidepressants; estrogen; combination if needed; Surgical techniques:; - -Uncomplicated, nonrecurrent SUI due to hypermobility
Mixed (Urge-Stress) | With normal PVR, no complicating factors | | Combinations of above excluding surgical options in most cases

Table 4. Criteria for further evaluation [a]

| - Uncertain diagnosis and inability to develop a reasonable treatment plan based on the basic diagnostic evaluation. Uncertainty in diagnosis may occur when there is lack of correlation between symptoms and clinical findings.; - Failure to respond to the patient's satisfaction to an adequate therapeutic trial, and the patient is interested in pursuing further therapy.; - Consideration of surgical intervention, particularly if previous surgery failed or the patient is a high surgical risk.; - Hematuria without infection.; - The presence of other comorbid conditions, such as:; - - incontinence associated with recurrent symptomatic UTI; - - persistent symptoms of difficult bladder emptying; - - history of previous anti-incontinence surgery or radical pelvic surgery; - - beyond hymen and symptomatic pelvic prolapse; - - prostate nodule, asymmetry, or other suspicion of prostate cancer; - - abnormal PVR urine; - - neurologic condition, such as multiple sclerosis and spinal cord lesions or injury.

[a] Some patients who meet the criteria may not be appropriate for further evaluation and treatment if such evaluation and/or treatment is not desired by or feasible for the patient.

After the basic evaluation and initial treatment, patients who fail or those who are not appropriate for treatment based on presumptive diagnosis should undergo further evaluation. (Strength of Evidence = C.)

The objectives of further evaluation are as follows:

- Identify the specific cause or causes of UI with reproduction of leakage during testing.
- Identify conditions that cause similar symptoms but require different treatments, such as outlet obstruction, detrusor muscle weakness, urethral hypermobility, ISD, and urethral diverticulum.
- Detect functional, neurologic, or anatomic lesions affecting the lower urinary tract.
- Help obtain specific informtion necessary for choosing the appropriate therapy.
- Identify risk factors that may influence the outcome of a specific treatment.

### Specialized Tests

Specialized tests are not intended to be part of the basic evaluation of UI. (Strength of Evidence = B.)

Numerous specialized diagnostic tests are available, and the evaluation must be tailored to the question to be answered. Specialized tests include the following:

- Urodynamic tests.
- Endoscopic tests.
- Imaging tests.

Table 5 summarizes the major symptoms of incontinence, associated factors, conditions, and diagnostic test options. Although the primary care physician is not expected to be an expert in these techniques, health care providers should be familiar with the diagnostic tests that may be used in evaluating the symptoms of UI.

Table 5. Diagnostic test options [a]

Type of UI | Mechanism | | Associated factors | | Diagnostic test options
Urge | Unstable bladder or detrusor instability (DI) | | No neurologic deficit | | Simple or multichannel CMG with or without EMG
| Detrusor hyperreflexia (DH), detrusor sphincter dyssynergia (DSD) | | With neurologic lesion such as stroke, supraspinal cord lesions, multiple sclerosis | | Simple cystometry or multichannel
| Detrusor hyperactivity with impaired contractility (DHIC) | | Elderly, usually also associated with obstructive or stress symptoms | | Multichannel CMG with or without EMG Videourodynamics
Stress | Hypermobility of bladder neck (female) | | Detachment of bladder neck with concomitant hypermobility of the urethra. | | Provocative stress test (direct visualization) Tests for bladder neck hypermobility Simple or multichannel CMG (to exlude DI) UPP or leak point pressure Videourodynamics
| Intrinsic sphincter deficiency (ISD) | | Postoperative (after prostatectomy or anti-incontinence surgery), trauma, aging, radiation, congenital (epispadias) | | Same as above
| Neurogenic sphincter deficiency | | Neurogenic, sacral, or infrasacral lesion (e.g., myelomeningocele) | | Same as above EMG
Overflow | Overflow from underactive or acontractile detrusor | | Neurogenic (low spinal cord lesion, neuropathy, postradical pelvic surgery), idiopathic detrusor failure | | Elevated PVR volume Uroflowmetry Voiding CMG (pressure flow) with EMG Cystourethroscopy
| Overflow from outlet obstruction | | Male: prostate gland disease, urethral stricture Female: postoperative | | Same as above Videourodynamics

[a] The urodynamic tests listed here are not recommended for routine use but are options for patients who require further evaluation (see text and Table 2). For details on various tests, see text.

CMG = cystometrogram, EMG = electromyogram, PVR = postvoid residual, UPP = urethral pressure profilometry

#### Urodynamic Tests

These tests are designed to determine the anatomic and functional status of the urinary bladder and urethra. The tests are performed by qualified professionals trained in the specific definitions and procedures.

In the further evaluation of UI, simple cystometry is appropriate for detecting abnormalities of detrusor compliance and contractability, measuring PVR, and determining capacity. (Strength of Evidence = A.)

In some instances of complicated diagnostic situations or involved therapeutic plans, multichannel cystometric tests are appropriate. (Strength of Evidence = B.)

When performing urodynamic studies, the health care provider should attempt to reproduce the patient's symptoms. (Strength of Evidence = C.)

No published research supports a need for cystometric testing in routine or basic evaluation of UI. However, cystometric tests remain important in certain clinical conditions, such as the ones delineated in Table 4.

Cystometry is a test of detrusor function. Depending on the technique used, cystometry can be used to assess bladder sensation, capacity, and compliance, and to determine the presence and magnitude of both voluntary and involuntary detrusor contractions. The patient's symptoms should be reproduced at the time of cystometry, because involuntary DI may be observed in asymptomatic patients and symptomatic patients may show no evidence of involuntary ventrusial contractions. On the other hand, cystometry may be falsely negative in a patient with a genuinely overactive bladder (McGuire, 1994). This is caused by heightened psychological inhibition of reflex activity or lack of measurable increase of detrusor pressure, urethral pressure, or electromyographic activity, which may be dissipated by poor urethral resistance and must therefore be examined closely.

Simple cystometry can be used to detect detrusor contractions and abnormalities of bladder compliance, and to measure PVR and determine bladder capacity (Ouslander, Leach, and Staskin, 1989; Sand, Brubaker, and Novak, 1991). This procedure is performed by filling the bladder to capacity by means of a urethral catheter. Because a rectal or vaginal catheter is not used to monitor the abdominal pressure, results must be interpreted with caution, especially in uncooperative or demented patients. Compared with multichannel studies, simple cystometry has a reported 75-100 percent sensitivity, 69-89 percent specificity, and 74-91 percent positive predictive value for the diagnosis of DI (Fonda, Brimage, and D'Astoli, 1993; Sand, Brubaker, and Novak, 1991; Sutherst and Brown, 1984).

A multichannel or subtracted cystometrogram (CMG) with simultaneous measurement of intra-abdominal, total bladder, and true detrusor pressures can differentiate an involuntary detrusor contraction or deversed bladder compliance from an increase in intra-abdominal pressure. However, few data are available comparing multichannel cystometrics with other measures of intravesical pressure, and it is suspected that false positives may be a problem, especially in elderly populations (Diokno, Brown, Brock, et al., 1988). Likewise, ambulatory continuous monitoring may reveal detrusor contractions missed during a provocative subtracted CMG (McGuire, 1994).

A voiding CMG or pressure flow study can measure detrusor contractility and detect outlet obstruction if the patient is able to void. Simultaneous measurement of detrusor and urethral pressures during voiding is especially helpful in diagnosing urodynamic obstruction (Diokno, 1990).

Uroflowmetry measures the urine flow rate visually, electronically, or with the use of a disposable unit. An electronically generated flow curve is considered helpful in identifying abnormal voiding patterns. Uroflowmetry is not helpful in diagnosing the types of incontinence found in women (Diokno, Normolle, Brown, et al., 1990; Fantl, Smith, Schneider, et al., 1983), but it may be helpful in patients who have difficulty with bladder emptying. However, this test cannot distinguish between obstruction and detrusor weakness without a simultaneous measurement of detrusor function.

Urethral pressure profilometry (UPP). The urethral function test measures resting and dynamic pressures in the urethra. Passive measurement of urethral pressures has been used by some investigators to help identify ISD, especially in women who have had previous operations. However, no specific measurement to date has been found to be discriminatory, especially in the elderly because of the normal decline of urethral pressures with age (Diokno, Normolle, Brown, et al., 1990). Dynamic measurements of urethral and bladder pressures may be used to measure the effect of exertion on the urethral closure mechanism. Sphincter function can also be assessed by measuring the abdominal or vesical pressure needed to overcome the urethral resistance (McGuire, Fitzpatrick, Wan, et al., 1993; McGuire, Woodside, Borden, et al., 1981; Wan, McGuire, Bloom, et al., 1993). The relative usefulness of the UPP versus that of Abdominal Leak Point Pressure (ALPP) has not been adequately studied.

Electromyography (EMG) of the striated urethral sphincter measures the integrity and function of its innervation. Both needle and surface EMG, in conjunction with CMG, may be helpful in diagnosing DSD Diokno, Koff, and Anderson, 1976 ). However, this condition should be diagnosed only after common artifacts such as volitional tightening of the sphincter during involuntary detrusor contraction are excluded.

#### Endoscopic Tests

Cystoscopy is not recommended in the basic evaluation of UI. (Strength of Evidence = B.) However, cystoscopy may be indicated in the further evaluation when the following situations are present: (a) sterile hematuria or pyuria (Strength of Evidence = B); (b) when urodynamics fail to duplicate symptoms (Strength of Evidence = C); (c) new onset of irritative voiding symptoms, bladder pain, recurrent cystitis, or suspected foreign body. (Strength of Evidence = B.)

Cystourethroscopy is a procedure that may help in identifying bladder lesions and foreign bodies, as well as urethral diverticula, fistula, strictures, or ISD. Most experts agree that cystoscopy is indicated for the evaluation of incontinent patients who have sterile hematuria or pyuria; recent (weeks to months) onset of irritative voiding symptoms such as frequency, urgency, and urge incontinence in the absence of any reversible causes (seeTable 2); bladder pain; recurrent cystitis; or suspected intravesical foreign body; and when urodynamics fail to duplicate symptoms of UI.

A literature search revealed that in studies involving more than 600 incontinent patients selectively cystoscoped, only 11 (less than 2 percent) metaplastic or neoplastic lesions were identified (Awad, Gajewski, Katz, et al., 1992; Benson, 1985; Fischer-Rasmussen, Hansen, and Stage, 1986; Ouslander, Hepps, Raz, et al., 1986; Ouslander, Leach, Staskin, et al., 1989; Vehkalahti, Kivela, and Seppanen, 1986). Even in elderly, incontinent populations, the yield from selected cystoscopy is less than 1 percent Ouslander, Hepps, Raz, et al., 1986). Therefore, cystoscopy should not be performed routinely in incontinent patients to exclude neoplasm.

The precise role of cystoscopy in the evaluation of incontinent patients is controversial. Data are scarce in the literature on this issue, and studies have a referral bias. Furthermore, urethroscopy is not as useful as urodynamic tests in diagnosing SUI Scotti and Ostergard, 1993). Because this test is not performed during voiding, its usefulness in corroborating or excluding outlet obstruction is limited. Given the large numbers of patients with UI, and given the fact that the majority of UI patients are currently not cystoscoped, cystoscopy cannot be recommended as part of the routine evaluation until data are available to support its performance (Ouslander, Leach, and Staskin, 1989; Fischer-Rasmussen, Hansen, and Stage 1986).

#### Imaging Tests

Radiographic, ultrasonographic, and other imaging tests should be used for the evaluation of anatomic conditions associated with UI when clinically needed. (Strength of Evidence = C.)

Upper tract imaging is not a routine test to evaluate UI. Ultrasound of the kidneys, bladder, or both can help identify dilation of the upper urinary tract and renal pathology, especially in patients with urinary retention, abnormal renal function, or poorly compliant bladders. Excretory urography (i.e., intravenous pyelography) or other imaging modalities are indicated for incontinent patients with sterile hematuria or for further evaluation of upper tract obstruction or other pathology identified by ultrasound (Kumar and Schreib, 1985).

Lower tract imaging with and without voiding is helpful in examining the anatomy of the urinary bladder and urethra. Nonvoiding lateral cystourethrography in the resting and straining view can identify mobility or fixation of the bladder neck, funneling of the bladder neck and proximal urethra, and degree of cystocele. The voiding component can identify a urethral diverticulum, obstruction, and vesicoureteral reflux. Ultrasonography for assessing the dynamics of the bladder neck and urethra is still under investigation, and its clinical utility remains to be confirmed (Benson and Sumners, 1990; Mouritsen, Standberg, Jensen, et al., 1993; Quinn, Beynon, Mortensen, et al., 1988; Richmond and Sutherst, 1989b).

Videourodynamics is a technique that combines the various urodynamic tests with simultaneous fluoroscopy. The technique is helpful in sorting out causes of complex incontinence problems.