# Attachments

## Attachment A. Resources for Further Evaluation

American Academy of Neurology. Practice parameters for diagnosis and evaluation of dementia (summary statement): report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 1994;44:2203-6. [pmid: 7969988].
Clarfield AM. The reversible dementias: do they reverse?. Ann Intern Med. 1988;109:476-86. [pmid: 3046450].
Differential diagnosis of dementing diseases. NIH Consensus Statement 1987 July 6-8. 6(11):1-9.
McKhann G, Drachman D, Folstein M, et al. Clinical diagnosis of Alzheimer's disease: report of the NINCDS-ADRDA Work Group under the auspices of Department of Health and Human Services Task Force on Alzheimer's Disease. Neurology. 1984;34:939-44. [pmid: 6610841].
U.S. Department of Veterans Affairs. Dementia: guidelines for diagnosis and treatment, 1989 (revised). VA Publication No. IB 18-3.

## Attachment B. Instruments for Which Specific Literature Searches Were Conducted

- Mental-Status Exams
- Mini-Mental State Examination (MMSE)
- Mental Status Questionnaire (MSQ)
- Short Portable Mental Status Questionnaire (SPMSQ)
- Blessed Information-Memory-Concentration Test (BIMC)
- Abbreviated Mental Test (AMT)
- Blessed Orientation-Memory-Concentration Test (BOMC)
- Functional Capacity Measures
- Blessed Dementia Rating Scale (BDRS)
- Instrumental Activities of Daily Living (IADL)
- Short-CARE
- Lawton-Brody Physical Self-Maintenance Scale (PSMS)
- Psychogeriatric Dependency Rating Scale
- Functional Activities Questionnaire (FAQ)
- Verbal and Visual Memory Tests
- Selective Reminding (SR) Procedures, immediate
- Selective Reminding (SR) Procedures, delayed
- Word List Recall (CERAD), delayed
- Delayed Spatial Recognition Span
- Benton Visual Retention Test, delayed
- Constructional Ability/Praxis
- Clock Drawing Tests

## Attachment C. Comparison of Mental and Functional Status Tests According to Three Phases of Discrimination Difficulty

| Phase II | | | Phase III | | | Phase IV
| # Contr | D | Z | # Contr | D | Z | # Contr | D | Z
Mini-Mental State Examination (MMSE) | 8 | 4.08 | 0.00 | 19 | 2.40 | 0.00 | 12 | 1.78 | 0.00
26-item BIMC (Katzman et al., 1983) | 5 | 4.72 | 0.62 | 2 | 3.75 | [*]3.29 | 2 | 2.49 | 1.36
6-item BOMC (Katzman et al., 1983) | 2 | 6.51 | 1.36 | 1 | 3.79 | | 2 | 1.63 | -0.60
Short Test of Mental Status (STMS) | | | | | | | 2 | 2.01 | 0.39
Mental Status Questionnaire | 1 | 3.41 | | 1 | 2.11 | | 1 | 1.81
Short Portable MSQ | 1 | 10.09 | | 2 | 2.18 | -0.22 | 1 | 1.77
Functional Activities Questionnaire | | | | | | | 2 | 2.46 | [*]2.81
Associate Learning Recall of WMS | | | | 3 | 1.36 | -2.90
Assoc Learning Recall-Easy Pair (WMS) | 1 | 2.93 | | 1 | 1.25 | | 1 | 0.67
Assoc Learning Recall-Hard Pair (WMS) | 1 | 2.23 | | 1 | 1.75 | | 1 | 1.65
Delayed Logical Memory (WMS) | 3 | 3.76 | -0.29 | 4 | 3.41 | [*]2.04 | 1 | 2.34
Delay Visual Reproduction (WMS) | 3 | 2.57 | -2.05 | 3 | 2.62 | 0.49
Digit Span Backward (WMS) | | | | 1 | -0.16 | | 1 | 0.21
Digit Span Forward (WMS) | | | | 2 | 0.07 | -6.40 | 1 | 0.54
Immediate Logical Memory (WMS) | 3 | 2.83 | -1.85 | 8 | 2.08 | -0.79 | 1 | 1.58
Mental Control (WMS) | | | | 1 | -0.05 | | 1 | 0.07
Visual Reproduction (WMS) | 3 | 2.61 | -2.04 | 4 | 1.28 | -2.73 | 1 | 0.75
Verbal Fluency (Animals) | 2 | 3.29 | -0.88 | 6 | 1.87 | -1.36
Verbal Fluency (F) | | | | 2 | 2.14 | -0.61 | 1 | 0.50
Word Fluency (S) | | | | | | | 1 | 0.80
COWA (FAS) | 3 | 2.28 | -2.17 | 6 | 1.69 | -1.85
Blessed Dementia Scale | 3 | 2.96 | -0.81 | 2 | 2.38 | -0.06 | 1 | 0.55
Supermarket List Gen Test (DRS) | | | | 2 | 2.83 | 1.09 | 1 | 1.54
BVRT-Form C-Number Correct | 1 | 1.02 | | 3 | 1.94 | -1.33
BVRT-Form C-Number Errors | 1 | 1.15 | | 1 | 2.03 | | 1 | 0.82
BVRT Copying-Number Correct | 1 | 0.75 | | 1 | 0.35
BVRT Copying-Number Errors | 1 | 0.75 | | | | | 1 | 0.60
Selective Reminding-Total Words | 1 | 3.20 | | 3 | 2.48 | 0.11 | 2 | 2.75 | 1.28
Trailmaking Test-Part A | | | | 3 | 1.28 | -2.23 | 1 | 0.69
Trailmaking Test-Part | 1 | 4.08 | | 3 | 1.98 | -0.61
Porteus Maze Test | 1 | 3.11 | | 2 | 2.42 | 0.01
Symbol Digit Modalities | | | | 1 | 2.68 | | 2 | 1.82 | 0.19
Block Design (WAIS) | 1 | 2.93 | | 2 | 1.48 | 1.48 | -2.57 | 1.20 | -1.30
Comprehension (WAIS) | | | | 1 | 1.64 | | 2 | 0.98 | -3.56
Digit Span Forward (WAIS) | 1 | 1.81 | | 4 | 0.77 | -4.33 | 2 | 0.88 | -2.63
Digit Symbol (WAIS) | | | | 2 | 1.21 | -2.80 | 4 | 0.84 | -3.00
Information (WAIS) | | | | 1 | 1.43 | | 3 | 1.20 | -2.09
Picture Completion (WAIS) | 1 | 3.14 | | 1 | 1.74 | | 2 | 1.12 | -2.73
Similarities (WAIS) | 4 | 1.79 | -4.69 | 3 | 0.47 | -3.39 | 2 | 1.11 | -2.98
Vocabulary (WAIS) | 6 | 2.66 | -1.66 | 5 | 1.97 | -0.57 | 2 | 1.02 | -3.38
Block Design (WAIS-R) | 2 | 1.96 | -4.34 | 1 | 1.53 | | 2 | 1.18 | -1.81
Abbreviated Mental Test | | | | | | | 2 | 0.67 | -2.60
Kendrick Object Learning Test | | | | 1 | 3.68 | | 2 | 1.60 | -0.18
Kendrick Digit Copying Test | | | | 1 | 0.62 | | 1 | 1.05
Temporal Orientation | | | | 2 | 0.98 | -4.47
Token Test | | | | 2 | 1.27 | -2.44
Benton Test of Facial Recognition | 1 | 1.16 | | 6 | 1.08 | -4.30 | 1 | 2.08
Boston Naming Test | 1 | 2.87 | | 6 | 1.76 | -1.79 | 1 | 1.18
Category Retrieval | 1 | 16.65 | | 2 | 4.71 | 1.11
Bender-Gestalt Test | | | | 1 | 0.97
Cognitive Capacity Screening Exam | | | | 1 | 1.82 | | 1 | 2.02
Katz ADL | 1 | 6.48 | | 1 | 7.80

Source: Guideline panel.

Notes: Data extracted from studies and assembled by guideline panel. Analytic scheme adapted from Nierenberg AA, Feinstein AR. How to evaluate a diagnostic marker test. Lessons learned from the rise and fall of dexamethasone suppression test. JAMA 1988; 259(11):1699-1702.

Tests with Z scores of 1.96 or higher are significantly better than the "reference" test (MMSE) in distinguishing case patients from control subjects.

Numbers in boldface are randomized average effect size (RAVD); numbers in italics are mean effect size (D).

ADL = Activities of Daily Living Scale; BIMC = Blessed Information-Memory-Concentration Test; BOMC = Blessed Orientation- Memory-Concentration Test; BVRT = Benton Visual Retention Test; COWA = Controlled Oral Word Association; DRS = Dementia Rating Scale; MSQ = Mental Status Questionnaire; WAIS = Wechsler Adult Intelligence Scale; WAIS-R = Wechsler Adult Intelligence Scale Revised; WMS = Wechsler Memory Scale

Phase II = moderate to severe dementia in case patients, no comorbidity in control subjects. Phase III = mild to severe dementia in case patients, no comorbidity in control subjects. Phase IV = mild to severe dementia in case patients, comorbidity in control subjects.

Contr = control;

D = effect size;

2 Z = (test x minus MMSE) divided by square root of (SEtest x plus SEMMSE)

[*] p less than .05 one-tailed.

## Attachment D. Resources for Health Professionals, Patients, and Families

When a diagnosis of dementia is made, the patient and family members have serious issues to consider. Although followup beyond this point is desirable, it cannot be ensured. For this reason, the visit during which the diagnosis is given is an appropriate time for the clinician to mention relevant issues, which include but are not restricted to long-term financial, legal, and medical planning. The following list of resources can be helpful to families when they are ready to confront the many implications of a diagnosis of dementia. A consumer version of this guideline is also available (see inside back cover for ordering information).

### Administration on Aging

The Administration on Aging (AoA) coordinates delivery of services specified by the Older Americans Act. Services are coordinated and provided through 57 State agencies and 657 areas.

Agencies on Aging (AAAs). The range of services provided by each AAA varies, but all include nutrition services, access services, in-home services, and community services.

Addresses and phone numbers of State and area AAAs may be obtained from the national office:

- Administration on Aging
- Department of Health and Human Services
- 330 Independence Avenue, SW
- Washington, DC 20201
- (202) 619-1006, (202) 619-7586 fax
- Internet address: gopher://gopher.os.dhhs.gov/11/dhhs/aoa/aoa

The Elder Care Locator provides a toll-free access number to locate State agency networks: 800-667-1116.

### Alzheimer's Disease Centers

The National Institute on Aging, a component of the National Institutes of Health, supports 28 Alzheimer's Disease Centers across the country. This program provides clinical services, conducts basic and clinical research, disseminates professional and public information, and sponsors educational activities. A growing number of satellite clinics associated with this program are helping to expand diagnostic and treatment services in rural and minority communities and collect research data from a more diverse population. For information, contact the ADEAR Center (see below).

### Alzheimer's Association

The Alzheimer's Association is a national voluntary organization with 220 local chapters and more than 2,000 support groups. The Alzheimer's Association funds research, promotes public awareness, advocates legislation for patients and families, and provides support services, including support groups, adult day care programs, respite care programs, and telephone helplines through its national, local chapter, and volunteer network.

- Alzheimer's Association,
- 919 North Michigan Avenue, Suite 100
- Chicago, IL 60611-1676
- (312) 335-8700, 800-272-3900 for information and local chapter referrals nationwide (24-hour telephone line)
- Internet address: http://www.alz.org

### Alzheimer's Disease Education and Referral Center

The Alzheimer's Disease Education and Referral (ADEAR) Center, a service of the National Institute on Aging, provides information and publications on Alzheimer's disease for health professionals, people with Alzheimer's disease and their families, and the public. The ADEAR Center serves as a national resource for information on diagnosis, treatment issues, patient care, caregiver needs, long-term care, education, research, and ongoing programs. In addition, the Center provides referrals to national and State resources. For information, contact:

- Alzheimer's Disease Education and Referral Center
- P.O. Box 8250
- Silver Spring, MD 20907-8250
- 800-438-4380
- Internet address: adear@alzheimers.org

### The Corporation for National Service

The Corporation for National and Community Service is a public corporation that administers Federal service programs, including AmeriCorps, the Foster Grandparent Program, and the Senior Companion Program (SCP), which provides supportive services to adults with physical, emotional, and health limitations. A major emphasis of the SCP is preventing or delaying institutionalization. Foster Grandparent volunteers work with children, including those with disabilities. AmeriCorps members address a range of local health issues.

The address and phone number for regional offices may be obtained through the main office in Washington, DC.

- Corporation for National Service
- Office of Public Liaison
- 1201 New York Avenue, NW
- Washington, DC 20525
- (202) 606-5000

### Other Resources

- American Association of Retired Persons (AARP), Washington, DC, (202) 434-2277; 800-424-3410.
- AARP Pharmacy Price Quote Center, 800-456-2226
- American Bar Association Commission on Legal Problems of the Elderly, Washington, DC, (202) 662-8690
- Children of Aging Parents, Levittown, PA, (215) 945-6900
- Consortium to Establish a Registry for Alzheimer's Disease (CERAD), Durham, NC, (919) 286-6406 or 6405 National Association for Continence, Spartanburg, SC, 800-BLADDER (800-252-3337)
- Insurance Consumer Helpline, Washington, DC, 800-942-4242 Medicare Hotline, Baltimore, MD, 800-638-6833
- Medicare Beneficiaries Defense Fund, New York, NY, (212) 869-3850; 800-333-4114
- National Citizens' Coalition for Nursing Home Reform, Washington, DC, (202) 332-2275 National Hospice Organization, Arlington, VA, (703) 243-5900; 800-658-8898
- National Parkinson's Foundation, 800-327-4545, Miami, FL (East Coast); and 800-522-8855, Encino, CA (West Coast) National Stroke Association, Englewood, CO, (303) 771-1700; 800-STROKES.
- Social Security Information, 800-772-1213 (open 7 am-7 pm in all time zones) U.S. Department of Veterans Affairs, Regional Office, Veterans Assistance, Washington, DC, (202) 418-4343; 800-827-1000.