# Glossary

Activities of daily living (ADLs).: Self-maintenance skills such as dressing, bathing, toileting, grooming, eating, and ambulating.

Affective lability.: Rapidly changing or unstable expressions of emotion or mood.

Agnosia.: Loss or impairment of the ability to recognize, understand, or interpret sensory stimuli or features of the outside world, such as shapes or symbols.

Aphasia.: Prominent language dysfunction, affecting the ability to articulate ideas or comprehend spoken or written language.

Apraxia.: Loss or impairment of the ability to perform a learned motor act in the absence of sensory or motor impairment (e.g., paralysis or paresis).

Cognition.: The conscious faculty or process of knowing, including all aspects of awareness, perception, reasoning, thinking, and remembering.

Cognitive functions.: Mental processes, including memory, language skills, attention, and judgment (see also Table 6).

Comprehensive mental status examination.: Assessment of multiple cognitive functions that provides a detailed cognitive profile of the patient.

Confrontation naming.: The ability to name an object when shown a picture of it.

Delirium.: A temporary disordered mental state, characterized by acute and sudden onset of cognitive impairment, disorientation, disturbances in attention, decline in level of consciousness, or perceptual disturbances.

Dementia.: A syndrome of progressive decline in multiple areas (domains) of cognitive function eventually leading to a significant inability to maintain occupational and social performance.

Direct costs.: The expense of diagnostic, treatment, and care services.

Effect size.: A summary statistic that provides an index of the ability of a screening or test instrument to discriminate between, in this case, persons with and without dementia.

Episodic memory.: Memory of one's own experiences that is unique and localizable in time and space.

Executive functions.: Goal formulation, planning, and execution of plans.

Factor analysis.: A statistical procedure that is designed to determine if variability in scores can be related to one or more factors that are reliably influencing performance.

False-negative.: Erroneous finding of not having a particular medical condition (e.g., dementia) for a person who does have it.

False-positive.: Erroneous finding of a particular medical condition (e.g., dementia) for a person who does not have it.

Focused history.: A patient history confined to questions designed to elicit information related to cognitive impairment or a decline in function consistent with dementia and to document the chronology of the problems (Table 6).

Focused physical examination.: A physical examination that seeks to identify life-threatening or rapidly progressing illness, while paying special attention to conditions that might cause delirium. The examination typically includes a brief neurological evaluation as well as assessment of mobility and of cardiac, respiratory, and sensory functions.

Further assessment.: An additional evaluation, conducted after the initial assessment and intended to clarify information gleaned from that assessment, for the purpose of making a decision about the presence of a dementing disorder.

Incremental validity.: The notion that information from multiple, reliable sources enhances the validity of the assessment.

Indirect costs.: The expense of morbidity (the value of lost or reduced productivity of a patient, an unpaid caretaker, or both caused by illness) and mortality (the present value of future earnings lost because of premature death from disease).

Initial assessment (for dementia).: An evaluation conducted when the patient, clinician, or someone close to the patient first notices or mentions symptoms that suggest the presence of a dementing disorder. This evaluation includes a focused history, focused physical examination, examination of mental status and function, and consideration of confounding and comorbid conditions.

Instrumental activities of daily living (IADLs).: Complex, higher-order skills such as managing finances, using the telephone, driving a car, taking medications, planning a meal, shopping, and working in an occupation.

Meta-analysis.: Any systematic method that uses statistical analysis to integrate data from a number of independent studies.

Nonreversible dementias.: Term used to distinguish cognitive disorders that cannot be treated effectively to restore normal or nearly normal intellectual function from those that can.

Polypharmacy.: The administration of many drugs together.

Praxis.: The doing or performance of an action, movement, or series of movements.

Procedural memory.: Memory for certain ways of doing things or for certain movements.

Psychometric.: Relating to systematic measurement of mental processes; psychological variables such as intelligence, aptitude, and personality traits; and behavioral acts.

Reversible dementias.: Term used to distinguish cognitive disorders that can be treated effectively to restore normal or nearly normal intellectual function from those that cannot.

Semantic memory.: What is learned as knowledge; it is timeless and spaceless (e.g., the alphabet or historical data unrelated to a person's life).

Sensitivity (of a test instrument).: Ability to identify cases of a particular medical condition (e.g., dementia) in a population that includes persons who do not have it. Also called diagnostic sensitivity.

Specificity (of a test instrument).: Ability to identify those who do not have a particular medical condition (e.g., dementia) in a population that includes persons who do have it. Also called diagnostic specificity.

Standard deviation unit.: A measure of an approximate average of the amount by which each number in a set deviates from the mean of the set. The most commonly used measure of dispersion of statistical data.

Vascular dementia.: Dementia with a stepwise progression of symptoms, each with an abrupt onset, often in association with a neurologic incident. Also called multi-infarct dementia.

Visuospatial ability.: Capacity to produce and recognize three-dimensional or two-dimensional figures and objects.

Word fluency.: Ability to generate quickly a list of words that all belong to a common category or begin with a specific letter.