# Acronyms

ADLs: Activities of daily living

AHCPR: Agency for Health Care Policy and Research

AIDS: Acquired immunodeficiency syndrome ALS Amyotrophic lateral sclerosis

APA: American Psychological Association

apoE: Apolipoprotein E

BIMC: Blessed Information-Memory-Concentration [Test]

BOMC: Blessed Orientation-Memory-Concentration [Test] (also "short OMC")

CERAD: Consortium to Establish a Registry for Alzheimer's Disease

CES-D: Center for Epidemiological Studies Depression Scale

CSDD: Cornell Scale for Depression in Dementia

CUSPAD: Columbia University Scale for Psychopathology in Alzheimer's Disease

DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, fourth edition

FAQ: Functional Activities Questionnaire GDS Geriatric Depression Scale

HAM-D: Hamilton Depression Rating Scale

HIV: Human immunodeficiency virus

IADLs: Instrumental activities of daily living

ICD-9-CM: International Classification of Diseases, 9th revision, Clinical Modification

MMSE: Mini-Mental State Examination

NINCDS: National Institute of Neurological and Communicative

ADRDA: Disorders and Stroke-Alzheimer's Disease and Related Dementias Association

PSMS: Lawton-Brody Physical Self-Maintenance Skills

SAILS: Structured Assessment of Independent Living Skills

STMS: Short Test of Mental Status

WAIS-R: Wechsler Adult Intelligence Scale Revised