# References

Abranowicz M, editor. Drugs that cause psychiatric symptoms. Med Lett Drugs Ther. 1986;28:81-6. [pmid: 3528784].
Absher JR, Cummings JL. Dementia diagnosis and therapy in the elderly. Compr Ther. 1992;18:28-33. [pmid: 1643835].
/Advisory Panel on Alzheimer's Disease. Fourth report of the Advisory Panel on Alzheimer's Disease, 1992, Washington (DC):U.S. Government Printing Office;NIH Publication No. 93-3520 1993
Albert MS, Heller HS, Milberg W. Changes in naming ability with age. Psychol Aging. 1988;3:173-8. [pmid: 3268256].
Albert MS, Levkoff SE, Reilly C, et al. The delirium symptoms interview: an interview for the detection of delirium symptoms in hospitalized patients J Geriatr Psychiatry Neurol 1992 5 (1):14 21 1571069
/Albert MS, Moss MB, editors. Geriatric neuropsychology, New York:Guilford Press;1988
Alexopoulos GS, Abrams RC, Young RC, Shamoian CA. Cornell scale for depression in dementia. Biol Psychiatry. 1988;23:271-84. [pmid: 3337862].
/Alzheimer's Association. Is it Alzheimer's? Warning signs you should know, Chicago (IL):Alzheimer's Association;1995.
Amaducci L, Falcini M, Lippi A. Descriptive epidemiology and risk factors for Alzheimer's disease Acta Neurol Scand 1992; 139(suppl):21 5
American Academy of Neurology. Practice parameters for diagnosis and evaluation of dementia (summary statement): report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 1994;44:2203-6. [pmid: 7969988].
/American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 4th ed, Washington DC:American Psychiatric Association;1994
Anthony JC, LeResche LA, Niaz U, et al. Limits of the "Mini-Mental State" as a screening test for dementia and delirium among hospital patients. Psychol Med. 1982;12:397-408. [pmid: 7100362].
Anthony JC, LeResche LA, Von Korff MR, et al. Screening for delirium on a general medical ward: the tachistoscope and a global accessibility rating. Gen Hosp Psychiatry. 1985;7:36-42. [pmid: 3967822].
Arenberg D. Misclassification of "probable senile dementia Alzheimer's type" in the Baltimore Longitudinal Study of Aging. J Clin Epidemiol. 1990;43:105-7. [pmid: 2319274].
Arendt G, Hefter H, Neuen-Jacob E, et al. Electropsychological motor testing, MRI findings and clinical course in AIDS patients with dementia. J Neurol. 1993;240:439-45. [pmid: 8410087].
Arnold SE, Kumar A. Reversible dementias. Med Clin North Am. 1993;77:215-30. [pmid: 8419719].
Bachman DL, Wolf PA, Linn RT, et al. Incidence of dementia and probable Alzheimer's disease in a general population: the Framingham Study. Neurology. 1993;43:515-9. [pmid: 8450993].
Barberger-Gateau P, Commenges D, Gagnon M, et al. Instrumental activities of daily living as a screening tool for cognitive impairment and dementia in elderly community dwellers. J Am Geriatr Soc. 1992;40:1129-34. [pmid: 1401698].
Barry PB, Moskowitz MA. The diagnosis of reversible dementia in the elderly: a critical review. Arch Intern Med. 1988;148:1914-8. [pmid: 3046536].
Bassett SS, Folstein MF. Cognitive impairment and functional disability in the absence of psychiatric diagnosis. Psychol Med. 1991;21:77-84. [pmid: 2047508].
Bayles KA, Kaszniak AW. Communication and cognition in normal aging and dementia, Boston:College-Hill/Little, Brown; 1987
Bayles KA, Tomoeda CK. Caregiver report of prevalence and appearance order of linguistic symptoms in Alzheimer's patients. Gerontologist. 1991;31:210-6. [pmid: 2044993].
Becker JT, Bajulaiye O, Smith C. Longitudinal analysis of a two-component model of the memory deficit in Alzheimer's disease. Psychol Med. 1992;22:437-45. [pmid: 1615111].
/Benedict KB, Nacoste DB. Dementia and depression in the elderly: a framework for addressing difficulties in differential diagnosis. Clin Psychol Rev. 1990;10:513-37.
Berg L. Minor cognitive deficits and the detection of mild dementia Psychiatr J Univ Ottawa 1990 15(4):230 1
Blazer D, Hughes DC, George LK. The epidemiology of depression in an elderly community population. Gerontologist. 1987;27:281-7. [pmid: 3609795].
Blazer D, Williams CD. Epidemiology of dysphoria and depression in an elderly population. Am J Psychiatry. 1980;137:439-44. [pmid: 7361929].
Bleecker ML, Bolla-Wilson K, Kawas C, Agnew J. Age-specific norms for the Mini-Mental State Exam. Neurology. 1988;38:1565-8. [pmid: 3419600].
Blessed G, Tomlinson BE, Roth M. The association between quantitative measures of dementia and of senile change in the cerebral grey matter of elderly subjects Br J Psychiatry 1968 114(512):797 811 5662937
/Bondi MW, Kaszniak AW, Bayles KA, et al. Contributions of frontal system dysfunction to memory and perceptual abilities in Parkinson's disease. Neuropsychology. 1993;7:89-102.
Brayne C, Calloway P. The association of education and socioeconomic status with the Mini Mental State Examination and the clinical diagnosis of dementia in elderly people. Age Ageing. 1990;19:91-6. [pmid: 2337015].
Breitner JCS, Silverman JM, Mohs RC, et al. Familial aggregation in Alzheimer's disease: comparison of risk among relatives of early- and late-onset cases, and among male and female relatives in successive generations. Neurology. 1988;38:207-12. [pmid: 3340281].
Breitner JCS, Welsh KA. Diagnosis and management of memory loss and cognitive disorders among elderly persons. Psychiatr Serv. 1995;46:29-35. [pmid: 7895118].
Breteler MMB, Claus JJ, van Duijn CM, et al. Epidemiology of Alzheimer's disease. Epidemiol Rev. 1992;14:59-82. [pmid: 1289117].
/Brink TL, Yesavage JA, Lum O, et al. Screening tests for geriatric depression. Clin Gerontologist. 1982;1:37-43.
/Brust JCM. Neurological aspects of substance abuse, Boston: Butterworth-Heinemann; 1993
Burke WJ, Rubin EH, Morris JC, et al. Symptoms of "depression" in dementia of the Alzheimer type. Alzheimer Dis Assoc Disord. 1988;2:356-62. [pmid: 3196469].
/Burns A. Affective symptoms in Alzheimer's disease. Int J Geriatr Psychiatry. 1991;6:371-6.
Burns A, Folstein S, Brandt J, et al. Clinical assessment of irritability, aggression, and apathy in Huntington and Alzheimer disease. J Nerv Ment Dis. 1990;178:20-6. [pmid: 2136908].
Burns A, Jacoby R, Levy R. Progression of cognitive impairment in Alzheimer's disease. J Am Geriatr Soc. 1991;39:39-45. [pmid: 1987255].
Burns A, Lewis G, Jacoby R, et al. Factors affecting survival in Alzheimer's disease. Psychol Med. 1991;21:363-70. [pmid: 1876641].
Butler RN, Finkel SI, Lewis MI, et al. Aging and mental health, part 2: diagnosis of dementia and depression. Geriatrics. 1992;47:49-52, 55-7. [pmid: 1592268].
/Caird FI, Scott PJW. Drug-induced disease in the elderly: a critical survey of the literature. Drug-induced disorders series Vol. 2, Amsterdam: Elsevier Science;1986.
Callahan CM, Hendrie HC, Tierney WM. Documentation and evaluation of cognitive impairment in elderly primary care patients. Ann Intern Med. 1995;122:422-9. [pmid: 7856990].
/Cedarbaum JM, Gancher ST, editors. Parkinson's disease. Neurologic clinics Vol. 10, Philadelphia (PA): Saunders; 1992.
Celesia GG, Wanamaker WM. Psychiatric disturbances in Parkinson's disease. Dis Nerv Syst. 1972;33:577-83. [pmid: 4649149].
Chatterjee A, Strauss ME, Smyth KA, et al. Personality changes in Alzheimer's disease. Arch Neurol. 1992;49:486-91. [pmid: 1580810].
Chaves MLF, Izquierdo I. Differential diagnosis between dementia and depression: a study of efficiency increment. Acta Neurol Scand. 1992;85:378-82. [pmid: 1642108].
/Clarfield AM. Canadian consensus conference on the assessment of dementia; 5-6 October 1989, Montreal, Quebec:Canadian Consensus Conference on the Assessment of Dementia; 1991
Clarfield AM. The reversible dementias: do they reverse?. Ann Intern Med. 1988;109:476-86. [pmid: 3046450].
Cohen D, Eisdorfer C, Gorelick P, et al. Psychopathology associated with Alzheimer's disease and related disorders. J Gerontol. 1993;48:M255-60. [pmid: 8227995].
Cohen-Mansfield J, Marx MS, Rosenthal AS. Dementia and agitation in nursing home residents: how are they related?. Psychol Aging. 1990;5:3-8. [pmid: 2317299].
/Congress of the United States. Losing a million minds: confronting the tragedy of Alzheimer's disease and other dementias Congressional Summary, 1987. Report No. OTA-BA-32t, Washington, DC:Office of Technology Assessment;1989
Corder EH, Saunders AM, Risch NJ, et al. Protective effect of apolipoprotein E type 2 allele for late onset Alzheimer disease. Nat Genet. 1994;7:180-3. [pmid: 7920638].
Corey-Bloom J, Galasko D, Hofstetter CR, et al. Clinical features distinguishing large cohorts with possible AD, probable AD, and mixed dementia. J Am Geriatr Soc. 1993;41:31-7. [pmid: 8418119].
/Costa PT Jr, McCrae RR. NEO-PI/NEO-FFI manual supplement, Odessa (FL): Psychological Assessment Resources;1989
Cotrell V, Schulz R. The perspective of the patient with Alzheimer's disease: a neglected dimension of dementia research. Gerontologist. 1993;33:205-11. [pmid: 8468013].
/Cromwell SL. Antecedents and consequences of perceived memory adequacy in elders [dissertation], Tucson (AZ):, University of Arizona; 1992
Crook TH, West RL. Name recall performance across the adult life-span. Br J Psychol. 1990;81:335-49. [pmid: 2224395].
Crum RM, Anthony JC, Bassett SS, et al. Population-based norms for the Mini-Mental State Examination by age and educational level. JAMA. 1993;269:2386-91. [pmid: 8479064].
/Cummings JL, Benson DF. Dementia: a clinical approach 2nd ed, Boston: Butterworth-Heinemann; 1992
/Davis K, Neuman P. Financing care for patients with Alzheimer's disease and related disorders. Prepared for the Office of Technology Assessment Workshop on Financing Care for Patients With Alzheimer's Disease and Related Disorders. Economics, Social Science and Health Services Research, Dementia Working Papers Vol. 2, Springfield (VA):National Technical Information Service; 1986
/Delis DC, Massman PJ, Butters N, et al. Profiles of demented and amnesic patients on the California Verbal Learning Test: implications for the assessment of memory disorders. Psychol Assess: J Consult Clin Psychol. 1991;3:19-26.
Deutch LH, Deutsch LH, Rovner BW. Agitation and other noncognitive abnormalities in Alzheimer's disease. Psychiatr Clin North Am. 1991;14:341-51. [pmid: 1676506].
Devanand DP, Miller L, Richards M, et al. The Columbia University Scale for Psychopathology in Alzheimer's Disease. Arch Neurol. 1992;49:371-6. [pmid: 1558517].
Differential diagnosis of dementing diseases. NIH Consensus Statement 1987 July 6-8. 6(11):1-9.
Duchek JM, Cheney M, Ferraro FR, et al. Paired associate learning in senile dementia of the Alzheimer type. Arch Neurol. 1991;48:1038-40. [pmid: 1929895].
Erkinjuntti T, Wikström J, Palo J, et al. Dementia among medical inpatients: evaluation of 2000 consecutive admissions. Arch Intern Med. 1986;146:1923-6. [pmid: 3767536].
Ernst RL, Hay JW. The US economic and social costs of Alzheimer's disease revisited. Am J Public Health. 1994;84:1261-4. [pmid: 8059882]. [pmcid: 1615456].
Escobar JI, Burnam A, Karno M, et al. Use of the Mini-Mental Status Examination (MMSE) in a community population of mixed ethnicity: cultural and linguistic artifacts. J Nerv Ment Dis. 1986;174:607-14. [pmid: 3760851].
Evans DA, Funkenstein HH, Albert MS, et al. Prevalence of Alzheimer's disease in a community population of older persons: higher than previously reported. JAMA. 1989;262:2551-6. [pmid: 2810583].
Evans DA, Scherr PA, Cook NR, et al. Estimated prevalence of Alzheimer's disease in the United States. Milbank Q. 1990;68:267-89. [pmid: 2233632].
Feher EP, Larrabee GJ, Crook TH III. Factors attenuating the validity of the Geriatric Depression Scale in a dementia population. J Am Geriatr Soc. 1992;40:906-9. [pmid: 1512387].
Flicker C. Neuropsychological evaluation of treatment effects in the elderly: a critique of tests in current use. Psychopharmacol Bull. 1988;24:535-56. [pmid: 3074315].
Flicker C, Ferris SH, Reisberg B. Mild cognitive impairment in the elderly: predictors of dementia. Neurology. 1991;41:1006-9. [pmid: 2067629].
Folstein MF, Bassett SS, Anthony JC, et al. Dementia: case ascertainment in a community survey. J Gerontol. 1991;46:M132-8. [pmid: 2071834].
Folstein MF, Folstein SE, McHugh PR. "Mini-Mental State": a practical method for grading the cognitive state of patients for the clinician. J Psychiatr Res. 1975;12:189-98. [pmid: 1202204].
Fratiglioni L, Grut M, Forsell Y, et al. Prevalence of Alzheimer's disease and other dementias in an elderly urban population: relationship with age, sex, and education. Neurology. 1991;41:1886-92. [pmid: 1745343].
/Fry PS. Depression, stress, and adaptations in the elderly: psychological assessment and intervention, Rockville (MD):Aspen; 1986
/Fuld PA. The Fuld Object-Memory Evaluation, Chicago:Stoelting Instrument Co.; 1981
/Gallagher D. Assessment of depression by interview methods and psychiatric rating scales. In: Poon LW, editor. Handbook for clinical memory assessment in older adults, Washington (DC):American Psychological Association; 1986. p. 202 12
Ganguli M, Ratcliff G, Huff FJ, et al. Effects of age, gender, and education on cognitive tests in a rural elderly community sample: norms from the Monongahela Valley Independent Elders Survey. Neuroepidemiology. 1991;10:42-52. [pmid: 2062416].
Garcia CA, Reding MJ, Blass JP. Overdiagnosis of dementia. J Am Geriatr Soc. 1981;29:407-10. [pmid: 7264133].
German PS, Shapiro S, Skinner EA, et al. Detection and management of mental health problems of older patients by primary care providers. JAMA. 1987;257:489-93. [pmid: 3540329].
Gottlieb GL, Johnson J, Wanich C, et al. Delirium in the medically ill elderly: operationalizing the DSM-III criteria. Int Psychogeriatr. 1991;3:181-96. [pmid: 1811772].
Grafman J, Weingartner H, Newhouse PA, et al. Implicit learning in patients with Alzheimer's disease. Pharmacopsychiatry. 1990;23:94-101. [pmid: 2339182].
/Grant I, Adams KM, editors. Neuropsychological assessment of neuropsychiatric disorders, New York: Oxford University Press; 1986.
Graves AB, White E, Koepsell TD, et al. A case-control study of Alzheimer's disease. Ann Neurol. 1990;28:766-74. [pmid: 2285263].
Green CR, Mohs RC, Schmeidler J, et al. Functional decline in Alzheimer's disease: a longitudinal study. J Am Geriatr Soc. 1993;41:654-61. [pmid: 8505464].
Greene MG, Majerovitz SD, Adelman RD, et al. The effects of the presence of a third person on the physician-older patient medical interview. J Am Geriatr Soc. 1994;42:413-9. [pmid: 8144827].
Grut M, Jorm AF, Fratiglioni L, et al. Memory complaints of elderly people in a population survey: variation according to dementia stage and depression. J Am Geriatr Soc. 1993;41:1295-1300. [pmid: 8227910].
/Gurland BJ, Cross P, Chen J, et al. A new performance test of adaptive cognitive functioning: the medication management (MM) test. Int J Geriatr Psychiatry. 1994;9:875-85.
/Gurland BJ, Wilder DE, Chen J, et al. A flexible system of detection for Alzheimer's disease and related dementias. Aging Clin Exp Res. 1995;7:165-72.
/Gurland BJ, Wilder DE, Cross P, et al. Relative rates of dementia by multiple case definitions over two prevalence periods in three sociocultural groups. Am J Geriatr Psychiatry. 1995;3:6-20.
Harris MJ, Gierz M, Lohr JB. Recognition and treatment of depression in Alzheimer's disease. Geriatrics. 1989;44:26-30. [pmid: 2687119].
Hart S. Language and dementia: a review. Psychol Med. 1988;18:99-112. [pmid: 3283810].
Hasselblad V, Hedges LV. Meta-analysis of screening and diagnostic tests. Psychol Bull. 1995;117:167-78. [pmid: 7870860].
Hay JW, Ernst RL. The economic costs of Alzheimer's disease. Am J Public Health. 1987;77:1169-75. [pmid: 3113273]. [pmcid: 1647016].
/Heaton RK, Grant I, Matthews CG. Differences in neuropsychological test performance associated with age, education, and sex. In: Grant I, Adams KM, editors. Neuropsychological assessment of neuropsychiatric disordersNew York, Oxford University Press; 1986 p. 100 20
Heaton RK, Pendleton MG. Use of neuropsychological tests to predict adult patients' everyday functioning. J Consult Clin Psychol. 1981;49:807-21. [pmid: 7309951].
/Hedges LV, Okin I. Statistical methods for meta-analysis. San Diego (CA): Academic Press. 1985.
Heller RB, Dobbs AR, Rule BG. Communicative function in patients with questionable Alzheimer's disease. Psychol Aging. 1992;7:395-400. [pmid: 1388860].
/Henderson AS. Epidemiology of dementia disorders. In: Wurtman RJ, Corkin S, Growdon JH, Ritter-Walker E, editors. Advances in neurology. Vol. 51: Alzheimer's disease, New York:Raven Press;1990. p. 15 25
Henderson AS, Huppert FA. The problem of mild dementia [editorial]. Psychol Med. 1984;14:5-11. [pmid: 6709792].
Henderson VW, Mack W, Williams BW. Spatial disorientation in Alzheimer's disease. Arch Neurol. 1989;46:391-4. [pmid: 2705898].
Hershey LA, Jaffe DF, Greenough PG, et al. Validation of cognitive and functional assessment instruments in vascular dementia. Int J Psychiatry Med. 1987;17:183-92. [pmid: 3610484].
Heyman A, Fillenbaum G, Prosnitz B, et al. Estimated prevalence of dementia among elderly black and white community residents. Arch Neurol. 1991;48:594-8. [pmid: 2039381].
Hof PR, Bouras C, Constantinidis J, et al. Selective disconnection of specific visual association pathways in cases of Alzheimer's disease presenting with Balint's syndrome. J Neuropathol Exp Neurol. 1990;49:168-84. [pmid: 2307982].
Hoffman RS. Diagnostic errors in the evaluation of behavioral disorders. JAMA. 1982;248:964-7. [pmid: 7097965].
Howieson DB, Holm LA, Kaye JA, et al. Neurologic function in the optimally healthy oldest old: neuropsychological evaluation. Neurology. 1993;43:1882-6. [pmid: 8413942].
Hu TW, Huang LF, Cartwright WS. Evaluation of the costs of caring for the senile demented elderly: a pilot study. Gerontologist. 1986;26:158-63. [pmid: 3710237].
Huang LF, Cartwright WS, Hu TW. The economic cost of senile dementia in the United States, 1985. Public Health Rep. 1988;103:3-7. [pmid: 3124195].
Hultsch DF, Hertzog C, Small BJ, et al. Short-term longitudinal change in cognitive performance in later life. Psychol Aging. 1992;7:571-84. [pmid: 1466826].
Hyman BT, West HL, Rebeck GW, et al. Quantitative analysis of senile plaques in Alzheimer's disease: observation of log-normal size distribution and particular molecular epidemiology of differences associated with APOE genotypes and trisomy 21 Down syndrome. Proc Natl Acad Sci U S A. 1995;92:3586-90. [pmid: 7724603]. [pmcid: 42212].
Inouye SK, van Dyck CH, Alessi CA, et al. Clarifying confusion: the Confusion Assessment Methoda new method for detection of delirium. Ann Intern Med. 1990;113:941-8. [pmid: 2240918].
Inouye SK, Viscoli CM, Horwitz RI, et al. A predictive model for delirium in hospitalized elderly medical patients based on admission characteristics. Ann Intern Med. 1993;119:474-81. [pmid: 8357112].
Johnson JC, Kerse NM, Gottlieb G, et al. Prospective versus retrospective methods of identifying patients with delirium. J Am Geriatr Soc. 1992;40:316-9. [pmid: 1556357].
/Jorm AF. The epidemiology of Alzheimer's disease and related disorders, London: Chapman & Hall;1990.
Jorm AF, Korten AE. Assessment of cognitive decline in the elderly by informant interview. Br J Psychiatry. 1988;152:209-13. [pmid: 3167337].
/Kaeming KL, Kaszniak AW. Neuropsychological aspects of human immunodeficiency virus infection. Clin Neuropsychol. 1989;3:309-26.
Kahn RL, Zarit SH, Hilbert NM, et al. Memory complaint and impairment in the aged: the effect of depression and altered brain function. Arch Gen Psychiatry. 1975;32:1569-73. [pmid: 1200775].
/Kaszniak AW, Allender J. Psychological assessment of depression in older adults. In: Chaisson-Stewart GM, editor. Depression in the elderly: an interdisciplinary approach, New York:Wiley; 1985. p. 107 60
Kaszniak AW, Fox J, Gandell DL, et al. Predictors of mortality in presenile and senile dementia. Ann Neurol. 1978;3:246-52. [pmid: 666265].
Kaszniak AW, Keyl PM, Albert MS. Dementia and the older driver. Hum Factors. 1991;33:527-37. [pmid: 1769673].
/Kaszniak AW, Sadeh M, Stern LZ. Differentiating depression from organic brain syndromes in older age. In: Chaisson-Stewart GM, editor. Depression in the elderly: an interdisciplinary approach, New York: Wiley; 1985. p. 161 89
Kaszniak AW, Wilson RS, Fox JH, et al. Cognitive assessment in Alzheimer's disease: cross-sectional and longitudinal perspectives. Can J Neurol Sci. 1986;13:420-3. [pmid: 3491663].
/Katz S, Ford AB, Moskowitz RW, et al. Studies of illness in the aged. The index of ADL: a standardized measure of biological and psychosocial function. JAMA. 1963;185:914-9. [pmid: 14044222].
Katzman R, Brown T, Fuld P, et al. Validation of a short orientation-memory-concentration test of cognitive impairment. Am J Psychiatry. 1983;140:734-9. [pmid: 6846631].
/Katzman R, Lasker B, Bernstein N. Advances in the diagnosis of dementia: accuracy of diagnosis and consequences of misdiagnosis of disorders causing dementia. In: Terry RD, editor. Aging and the brain, New York:Raven Press; 1988. p. 17 62
/Katzman R, Rowe JW, editors. Principles of geriatric neurology, Philadelphia: FA Davis; 1992.
/Katzman R, Terry RD, Bick KL, editors. Alzheimer's disease: senile dementia and related disorders. Aging series. Vol. 7, New York:Raven;1978
Kemper S, LaBarge E, Ferraro FR, et al. On the preservation of syntax in Alzheimer's disease: evidence from written sentences. Arch Neurol. 1993;50:81-6. [pmid: 8418805].
Khachaturian ZS. Diagnosis of Alzheimer's disease. Arch Neurol. 1985;42:1097-105. [pmid: 2864910].
/Kiloh LG. Pseudo-dementia. Acta Psychiatr Scand. 1961;37:336-51. [pmid: 14455934].
/Klerman GL. Problems in the definition and diagnosis of depression in the elderly. In: Breslau LD, Haug MR, editors. Depression and aging: causes, care and consequences, New York:Springer; 1983 p. 3 19
Knopman D. Long-term retention of implicitly acquired learning in patients with Alzheimer's disease. J Clin Exp Neuropsychol. 1991;13:880-94. [pmid: 1779028].
Knopman DS, Ryberg S. A verbal memory test with high predictive accuracy for dementia of the Alzheimer type. Arch Neurol. 1989;46:141-5. [pmid: 2916953].
/Koenig HG, Blazer DG. Mood disorders and suicide. In: Birren JE, Sloane RB, Cohen GD, et al., editors. Handbook of mental health and aging. 2nd ed, San Diego: Academic Press;1992 p. 379 407
Kokmen E, Naessens JM, Offord KP. A Short Test of Mental Status: description and preliminary results. Mayo Clin Proc. 1987;62:281-8. [pmid: 3561043].
/Kolb B, Whishaw IQ. Fundamentals of human neuropsychology. 3rd ed, New York: WH Freeman; 1990.
/Koskinen T. Pseudodementia as a manifestation of depression in the elderly. Psychiatr Fenn. 1992;23:123-9.
/LaBarge E, Balota DA, Storandt M, et al. An analysis of confrontation naming errors in senile dementia of the Alzheimer type. Neuropsychology. 1992;6:77-95.
/LaBarge E, Rosenman LS, Leavitt K, et al. Counseling clients with mild senile dementia of the Alzheimer's type: a pilot study. J Neurol Rehab. 1988;2:167-73.
LaBarge E, Smith DS, Dick L, et al. Agraphia in dementia of the Alzheimer type. Arch Neurol. 1992;49:1151-6. [pmid: 1444882].
/Lanska DJ, Schoenberg BS. The epidemiology of dementia: methodologic issues and approaches. In: Whitehouse PJ, editor. Dementia, Philadelphia (PA):FA Davis; 1993. p. 3 33
Larrabee GL, Levin HS. Memory self-ratings and objective test performance in a normal elderly sample. J Clin Exp Neuropsychol. 1986;8:275-84. [pmid: 3722352].
Larson EB, Kukull WA, Buchner D, et al. Adverse drug reactions associated with global cognitive impairment in elderly persons. Ann Intern Med. 1987;107:169-73. [pmid: 2886086].
Larson EB, Reifler BV, Featherstone HJ, et al. Dementia in elderly outpatients: a prospective study. Ann Intern Med. 1984;100:417-23. [pmid: 6696360].
Larson EB, Reifler BV, Sumi SM, et al. Diagnostic evaluation of 200 elderly outpatients with suspected dementia. J Gerontol. 1985;40:536-43. [pmid: 4031401].
Larson EB, Reifler BV, Sumi SM, et al. Diagnostic tests in the evaluation of dementia: a prospective study of 200 elderly patients. Arch Intern Med. 1986;146:1917-22. [pmid: 3767535].
/La Rue A. Aging and neuropsychological assessment, New York: Plenum; 1992.
La Rue A, Watson J, Plotkin DA. Retrospective accounts of dementia symptoms: are they reliable?. Gerontologist. 1992;32:240-5. [pmid: 1577320].
/La Rue A, Yang J, Osato S. Neuropsychological assessment. In: Birren JE, Sloane RB, Cohen GD, editors. Handbook of mental health and aging 2nd ed, San Diego (CA):Academic Press;1992 p. 643 70
Lawton MP, Brody EM. Assessment of older people: self-maintaining and instrumental activities of daily living. Gerontologist. 1969;9:179-86. [pmid: 5349366].
Lazarus LW, Newton N, Cohler B, et al. Frequency and presentation of depressive symptoms in patients with primary degenerative dementia. Am J Psychiatry. 1987;144:41-5. [pmid: 3799838].
/Lesher EL. Validation of the Geriatric Depression Scale among nursing home residents. Clin Gerontol. 1986;4:21-8.
Levkoff S, Cleary P, Liptzin B, et al. Epidemiology of delirium: an overview of research issues and findings. Int Psychogeriatr. 1991;3:149-67. [pmid: 1811770].
Levkoff SE, Evans DA, Liptzin B, et al. Delirium: the occurrence and persistence of symptoms among elderly hospitalized patients. Arch Intern Med. 1992;152:334-40. [pmid: 1739363].
Levy-Lahad E, Wijsman EM, Nemens E, et al. A familial Alzheimer's disease locus on chromosome 1. Science. 1995;269:970-2. [pmid: 7638621].
/Lezak MD. Neuropsychological assessment. 3rd ed, New York: Oxford University Press; 1995
/Lipowski ZJ. Delirium: acute brain failure in man. 2nd ed, New York: Oxford University Press;1990.
/Loewenstein DA. Objective assessment of functional status in Alzheimer's disease and related disorders. Clin Gerontol. 1990;10:61-4.
/Loewenstein DA, Argüelles T, Barker WW, et al. A comparative analysis of neuropsychological test performance of Spanish-speaking and English-speaking patients with Alzheimer's disease. J Gerontol. 1993;48:142-9.
/Logie SA, Murphy JB, Brooks DN, et al. Diagnosis of depression in patients with dementia: use of the Cambridge Mental Disorders of the Elderly Examination (CAMDEX). Int J Geriatr Psychiatry. 1992;7:363-8.
/Lopez SR, Taussig IM. Cognitive-intellectual functioning of Spanish-speaking impaired and nonimpaired elderly; implications for culturally sensitive assessment. Psychol Assess. 1991;3:448-54.
Mackenzie TB, Robiner WN, Knopman DS. Differences between patient and family assessments of depression in Alzheimer's disease. Am J Psychiatry. 1989;146:1174-8. [pmid: 2764175].
Mahurin RK, DeBettignies BH, Pirozzolo FJ. Structured assessment of independent living skills: preliminary report of a performance measure of functional abilities in dementia. J Gerontol. 1991;46:58-66.
Mant A, Eyland EA, Pond DC, et al. Recognition of dementia in general practice: comparison of general practitioners' opinions with assessments using the Mini-Mental State Examination and the Blessed Dementia Rating Scale. Fam Pract. 1988;5:184-8. [pmid: 3224784].
McCartney JR, Palmateer LM. Assessment of cognitive deficit in geriatric patients: a study of physician behavior. J Am Geriatr Soc. 1985;33:467-71. [pmid: 4008844].
/McGlynn SM, Kaszniak AW. When metacognition fails: impaired awareness of deficit in Alzheimer's disease. J Cogn Neurosci. 1991;3:183-9.
McIntyre L, Frank J. Evaluation of the demented patient. J Fam Prac. 1987;24:399-404.
McKhann G, Drachman D, Folstein M, et al. Clinical diagnosis of Alzheimer's disease: report of the NINCDS-ADRDA Work Group under the auspices of Department of Health and Human Services Task Force on Alzheimer's Disease. Neurology. 1984;34:939-44. [pmid: 6610841].
Mendez MF, Mendez MA, Martin R, et al. Complex visual disturbances in Alzheimer's disease. Neurology. 1990;40:439-43. [pmid: 2314585].
Merriam AE, Aronson MK, Gaston P, et al. The psychiatric symptoms of Alzheimer's disease. J Am Geriatr Soc. 1988;36:7-12. [pmid: 3335733].
/Miller NE. The measurement of mood in senile brain disease: examiner ratings and self-reports. In: Cole JO, Barrett JE, editors. Psychopathology in the aged, New York: Raven Press;1980 . p. 97 118
Mitrushina M, Satz P. Utility of Mini-Mental State Examination in assessing cognition in the elderly. Aging. 1994;6:427-32. [pmid: 7748916].
Mohs RC, Breitner JCS, Silverman JM, et al. Alzheimer's disease: morbid risk among first-degree relatives approximates 50% by 90 years of age. Arch Gen Psychiatry. 1987;44:405-8. [pmid: 3579492].
Morris JC. Differential diagnosis of Alzheimer's disease. Clin Geriatr Med. 1994;10:257-76. [pmid: 8039098].
Morris JC, McKeel DW Jr, Storandt M, et al. Very mild Alzheimer's disease: informant-based clinical, psychometric, and pathologic distinction from normal aging. Neurology. 1991;41:469-78. [pmid: 2011242].
Morrison RL, Katz IR. Drug-related cognitive impairment: current progress and recurrent problems. Annu Rev Gerontol Geriatr. 1989;9:232-79. [pmid: 2514767].
/Mortimer JA. What are the risk factors for dementia? In: Huppert FA, Brayne C, O'Connor DW, editors. Dementia and normal aging, Cambridge (UK):Cambridge University Press;1994. p. 208 29
/Mortimer JA, Graves AB. Education and other socioeconomic determinants of dementia and Alzheimer's disease Neurology 1993 43(suppl 4):S39 S44 8389010
/Mortimer JA, Hutton JT. Epidemiology and etiology of Alzheimer's disease. In: Hutton JT, Kenny AD, editors. Senile dementia of the Alzheimer type. Neurology and neurobiology Vol. 18, New York: Alan R. Liss; 1985. p. 177 96
Mortimer JA, van Duijn CM, Chandra V, et al. Head trauma as a risk factor for Alzheimer's disease: a collaborative re-analysis of case-control studies Int J Epidemiol 1991 20(suppl 2):S28 S35 1833351
Murden RA, McRae TD, Kaner S, et al. Mini-Mental State Exam scores vary with education in blacks and whites. J Am Geriatr Soc. 1991;39:149-55. [pmid: 1991947].
Nathan BP, Bellosta S, Sanan DA, et al. Differential effects of apolipoproteins E3 and E4 on neuronal growth in vitro. Science. 1994;264:850-2. [pmid: 8171342].
/National Institute on Aging. Alzheimer's disease costs the nation an estimated 90 billion dollars per year: progress report on Alzheimer's disease, Bethesda (MD): National Institute on Aging; 1993NIH Publication No. 93-3409 (Discoveries in Health for Aging Americans series)
National Institutes of Health. Consensus Development Panel on Depression in Late Life. Diagnosis and treatment of depression in late life. JAMA. 1992;268:1018-24. [pmid: 1501308].
/Naugle RI, Cullum CM, Bigler ED. Evaluation of intellectual and memory function among dementia patients who were intellectually superior. Clin Neuropsychol. 1990;4:355-74.
Nebes RD. Semantic memory in Alzheimer's disease. Psychol Bull. 1989;106:377-94. [pmid: 2682718].
Nebes RD, Brody CP. Integrity of semantic fields in Alzheimer's disease. Cortex. 1988;24:291-9. [pmid: 3416611].
Nebes RD, Norton DC, Horn LL. Sparing of semantic memory in Alzheimer's disease. J Abnormal Psychol. 1984;93:321-30.
Nelson A, Fogel BS, Faust D. Bedside cognitive screening instruments: a critical assessment. J Nerv Ment Dis. 1986;174:73-83. [pmid: 3944597].
Nelson HE, O'Connell A. Dementia: the estimation of premorbid intelligence levels using the New Adult Reading Test. Cortex. 1978;14:234-44. [pmid: 679704].
Nierenberg AA, Feinstein AR. How to evaluate diagnostic marker tests. Lessons from the rise and fall of dexamethasone suppression test JAMA 1988 259(11):1699 1702 3278149
O'Brien ME. The dementia syndromes: distinguishing their clinical differences. Postgrad Med. 1994;95:91-3, 97-9, 101. [pmid: 8153050].
O'Connor DW, Fertig A, Grande MJ, et al. Dementia in general practice: the practical consequences of a more positive approach to diagnosis. Br J Gen Pract. 1993;43:185-8. [pmid: 8347384]. [pmcid: 1372389].
O'Connor DW, Pollitt PA, Hyde JB, et al. Do general practitioners miss dementia in elderly patients?. Br Med J. 1988;297:1107-10. [pmid: 3143447]. [pmcid: 1834835].
O'Connor DW, Pollitt PA, Hyde JB, et al. The reliability and validity of the Mini-Mental State in a British community survey. J Psychiatr Res. 1989;23:87-96. [pmid: 2666647].
O'Connor DW, Pollitt PA, Hyde JB, et al. Clinical issues relating to the diagnosis of mild dementia in a British community survey. Arch Neurol. 1991;48:530-4. [pmid: 2021368].
/Parks RW, Zec RF, Wilson RS, editors. Neuropsychology of Alzheimer's disease and other dementias, New York: Oxford University Press; 1993
Parmelee PA, Katz IR, Lawton MP. Depression among institutionalized aged: assessment and prevalence estimation. J Gerontol. 1989;44:M22-9. [pmid: 2783434].
Paveza GJ, Cohen D, Eisdorfer C, et al. Severe family violence and Alzheimer's disease: prevalence and risk factors. Gerontologist. 1992;32:493-7. [pmid: 1427252].
Perls TT. The oldest old Sci Am 1995 272(1):70 5 7824916
Peters CA, Potter JF, Scholer SG. Hearing impairment as a predictor of cognitive decline in dementia. J Am Geriatr Soc. 1988;36:981-6. [pmid: 3171050].
Petry S, Cummings JL, Hill MA, et al. Personality alterations in dementia of the Alzheimer type. Arch Neurol. 1988;45:1187-90. [pmid: 3190498].
Petry S, Cummings JL, Hill MA, et al. Personality alterations in dementia of the Alzheimer type: a three-year follow-up study. J Geriatr Psychiatry Neurol. 1989;2:203-7. [pmid: 2635017].
/Pfeffer RI. A social function measure in the staging and study of dementia. In: Bergener M, Brocklehurst JC, Finkel SI, editors. Aging, health, and healing, New York:Springer; 1995.
Pfeffer RI, Kurosaki TT, Harrah CH, et al. Measurement of functional activities in older adults in the community. J Gerontol. 1982;37:323-9. [pmid: 7069156].
Philbrick JT, Horwitz RI, Feinstein AR. Methodologic problems of exercise testing for coronary artery disease: groups, analysis and bias. Am J Cardiol. 1980;46:807-12. [pmid: 7435391].
Pinholt EM, Kroenke K, Hanley JF, et al. Functional assessment of the elderly: a comparison of standard instruments with clinical judgment. Arch Intern Med. 1987;147:484-8. [pmid: 3827424].
Plude DJ, Milberg WP, Cerella J. Age differences in depicting and perceiving tridimensionality in simple line drawings. Exp Aging Res. 1986;12:221-5. [pmid: 3569399].
Poirier J, Davignon J, Bouthillier D, et al. Apolipoprotein E polymorphism and Alzheimer's disease. Lancet. 1993;342:697-9. [pmid: 8103819].
/Pollitt PA, O'Connor DW, Anderson L. Mild dementia: perceptions and problems. Ageing Soc. 1989;9:261-75.
Popkin MK, Tucker GJ. "Secondary" and drug-induced mood, anxiety, psychotic, catatonic, and personality disorders: a review of the literature. J Neuropsychiatry Clin Neurosci. 1992;4:369-85. [pmid: 1422165].
/Rabins PV. Does reversible dementia exist and is it reversible? [editorial]. Arch Intern Med. 1988;148.
Rabins PV, Mace NL, Lucas MJ. The impact of dementia on the family. JAMA. 1982;248:333-5. [pmid: 7087127].
Ransohoff DF, Feinstein AR. Problems of spectrum and bias in evaluating the efficacy of diagnostic tests. N Engl J Med. 1978;299:926-30. [pmid: 692598].
/Raskind MA, Peskind ER. Alzheimer's disease and other dementing disorders. In: Birren JE, Sloane RB, Cohen GD, editors. Handbook of mental health and aging. 2nd ed, San Diego (CA):Academic Press; 1992. p. 477 513
Reding M, Haycox J, Blass J. Depression in patients referred to a dementia clinic: a three-year prospective study. Arch Neurol. 1985;42:894-6. [pmid: 4026634].
Reifler BV, Larson E, Hanley R. Coexistence of cognitive impairment and depression in geriatric outpatients. Am J Psychiatry. 1982;139:623-6. [pmid: 7072849].
Reisberg B, Ferris SH, Franssen E. An ordinal functional assessment tool for Alzheimer's-type dementia. Hosp Community Psychiatry. 1985;36:593-5. [pmid: 4007814].
/Reisberg B, Franssen E, Sclan SG, et al. Stage specific incidence of potentially remediable behavioral symptoms in aging and Alzheimer disease. Bull Clin Neurosci. 1989;54:95-112.
Rice DP, Fox PJ, Max W, et al. The economic burden of Alzheimer's disease care. Health Aff (Millwood). 1993;12:164-76. [pmid: 8375811].
/Rice DP, Max W. Costs of aging-related illnesses: a synthesis of current studies. Final report to the Office of Demography of AgingNational Institute on Aging,1993
Roca RP, Klein LE, Kirby SM, et al. Recognition of dementia among medical patients. Arch Intern Med. 1984;144:73-5. [pmid: 6691777].
Roses AD, Strittmatter WJ, Pericak-Vance MA, et al. Clinical application of apolipoprotein E genotyping to Alzheimer's disease [letter]. Lancet. 1994;343:1564-5. [pmid: 7911881].
Roth ME. Advances in Alzheimer's disease. A review for the family physician. J Fam Pract. 1993;37:593-607. [pmid: 8245812].
Rovner BW, German PS, Broadhead J, et al. The prevalence and management of dementia and other psychiatric disorders in nursing homes. Int Psychogeriatr. 1990;2:13-24. [pmid: 2101294].
Royston ML, Mann D, Pickering-Brown S, et al. APOE 2 allele promotes longevity and protects patients with Down Syndrome from dementia. Neuroreport. 1994;5:2583-5. [pmid: 7696609].
/Rubin EH. Psychopathology of senile dementia of the Alzheimer type. In: Wurtman RJ, Corkin S, Growdon JH, Ritter-Walker E, editors. Advances in neurology, Vol. 51. Alzheimer's disease, New York: Raven Press; 1990. p. 53 9
Rubin EH, Kinscherf DA. Psychopathology of very mild dementia of the Alzheimer type. Am J Psychiatry. 1989;146:1017-21. [pmid: 2750973].
Rubin EH, Morris JC, Berg L. The progression of personality changes in senile dementia of the Alzheimer's type. J Am Geriatr Soc. 1987;35:721-5. [pmid: 3611563].
Rubin EH, Morris JC, Storandt M, et al. Behavioral changes in patients with mild senile dementia of the Alzheimer's type. Psychiatry Res. 1987;21:55-62. [pmid: 3602220].
Rubin EH, Zorumski CF, Burke WJ. Overlapping symptoms of geriatric depression and Alzheimer-type dementia. Hosp Community Psychiatry. 1988;39:1074-9. [pmid: 3068114].
Rubin SM, Glasser ML, Werckle MA. The examination of physicians' awareness of dementing disorders. J Am Geriatr Soc. 1987;35:1051-8. [pmid: 3680837].
Rush JA, Golden WE, Hall GW, et al. Depression in primary care: Volume I. Detection and diagnosis. Clinical Practice Guideline No. 5. AHCPR Publication No. 93-0550, Rockville (MD): Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services.April 1993
/Salzman C, editor. Clinical geriatric psychopharmacology. 2nd ed, Baltimore: Williams & Wilkins; 1992.
Sapir M. Re: Prevalence of Alzheimer's disease in a retirement community [letter]. Am J Epidemiol. 1988;127:1093-5. [pmid: 3358411].
Saunders AM, Schmader K, Breitner JCS, et al. Apolipoprotein E[epsilon] 4 allele distribution in late-onset Alzheimer's disease and in other amyloid-forming diseases. Lancet. 1993;342:710-1. [pmid: 8103823].
/Schaie KW. The optimization of cognitive functioning in old age: predictions based on cohort-sequential and longitudinal data. In: Baltes PB, Baltes MM, editors. Successful aging: perspectives from the behavioral sciences, Cambridge (MA): Cambridge University Press; 1990 p. 94 117
Schellenberg GD, Bird TD, Wijsman EM, et al. Genetic linkage evidence for a familial Alzheimer's disease locus on chromosome 14. Science. 1992;258:668-71. [pmid: 1411576].
Schoenberg BS, Anderson DW, Haerer AF. Severe dementia: prevalence and clinical features in a biracial US population. Arch Neurol. 1985;42:740-3. [pmid: 4026605].
/Scogin F. The concurrent validity of the Geriatric Depression Scale with depressed older adults. Clin Gerontol. 1987;7:23-31.
Sherrington R, Rogaev EI, Liang Y, et al. Cloning of a gene bearing missense mutations in early-onset familial Alzheimer's disease. Nature. 1995;375:754-60. [pmid: 7596406].
/Siegel B, Gershon S. Dementia, depression, and pseudodementia. In: Altman HJ, editor. Alzheimer's disease: problems, prospects, and perspectives, New York: Plenum;1986. p. 29 44
/Siegler IC, Poon LW, Madden DJ. Psychological aspects of normal aging. In: Busse E, Blazer DG, editors. The American Psychiatric Press textbook of geriatric psychiatry. 2nd ed, Washington (DC):American Psychiatric Press; 1995 p. 113 39
Siegler IC, Welsh KA, Dawson DV, et al. Ratings of personality change in patients being evaluated for memory disorders. Alzheimer Dis Assoc Disord. 1991;5:240-50. [pmid: 1781966].
Siu AL. Screening for dementia and investigating its causes. Ann Intern Med. 1991;115:122-32. [pmid: 2058860].
Skoog I, Nilsson L, Palmertz B, et al. A population-based study of dementia in 85-year-olds. N Engl J Med. 1993;328:153-8. [pmid: 8417380].
Small GW, Jarvik LF. The dementia syndrome. Lancet. 1982:1443-6. [pmid: 6129517].
/Smith CW, Byrne EJ, Arie T, et al. Diagnosis of dementia. II-diagnostic methods: a survey of current consultant practice and review of the literature. Int J Geriatr Psychiatry. 1992;7:323-9.
Smith JS, Kiloh LG. The investigation of dementia: results in 200 consecutive admissions. Lancet. 1981;824-7.
Somerfield MR, Weisman CS, Ury W, et al. Physician practices in the diagnosis of dementing disorders. J Am Geriatr Soc. 1991;39:172-5. [pmid: 1991948].
/Spector WD, Jackson ME. Correlates of disruptive behaviors in nursing homes: a reanalysis. J Aging Health. 1994;6:173-84. [pmid: 10133303].
Spitzer RL, Williams JBW, Kroenke K, et al. Utility of a new procedure for diagnosing mental disorders in primary care. The PRIME-MD 1000 Study. JAMA. 1994;272:1749-56. [pmid: 7966923].
/Spreen O, Strauss E. A compendium of neuropsychological tests: administration, norms, and commentary, New York: Oxford University Press;1991.
Sroka H, Elizan TS, Yahr MD, et al. Organic mental syndrome and confusional states in Parkinson's disease: relationship to computerized tomographic signs of cerebral atrophy. Arch Neurol. 1981;38:339-42. [pmid: 7236060].
Steele C, Rovner B, Chase GA, et al. Psychiatric symptoms and nursing home placement of patients with Alzheimer's disease. Am J Psychiatry. 1990;147:1049-51. [pmid: 2375439].
Stern Y, Albert M, Brandt J, et al. Utility of extrapyramidal signs and psychosis as predictors of cognitive and functional decline, nursing home admission, and death in Alzheimer's disease: prospective analysis from the Predictors Study. Neurology. 1994;44:2300-7. [pmid: 7991116].
Stern Y, Gurland B, Tatemichi TK, et al. Influence of education and occupation on the incidence of Alzheimer's disease. JAMA. 1994;271:1004-10. [pmid: 8139057].
Storandt M, Botwinick J, Danziger WL, et al. Psychometric differentiation of mild senile dementia of the Alzheimer's type. Arch Neurol. 1984;41:497-9. [pmid: 6721715].
/Storandt M, Stone K, LaBarge E. Deficits in reading performance in very mild dementia of the Alzheimer type. Neuropsychology. 1995;;9:174-5.
Stoudemire A, Hill C, Gulley LR, et al. Neuropsychological and biomedical assessment of depression-dementia syndromes. J Neuropsychiatry Clin Neurosci. 1989;1:347-61. [pmid: 2521082].
Strauss ME, Pasupathi M, Chatterjee A. Concordance between observers in descriptions of personality change in Alzheimer's disease. Psychol Aging. 1993;8:475-80. [pmid: 8292276].
Sultzer DL, Levin HS, Mahler ME, et al. A comparison of psychiatric symptoms in vascular dementia and Alzheimer's disease. Am J Psychiatry. 1993;150:1806-12. [pmid: 8238634].
Teri L, McCurry SW, Edland SD, et al. Cognitive decline in Alzheimer's disease: a longitudinal investigation of risk factors for accelerated decline. J Gerontol. 1995;50A:M49-55.
Teri L, Wagner A. Alzheimer's disease and depression. J Consult Clin Psychol. 1992;60:379-91. [pmid: 1619092].
/Terry RD, Katzman R, Bick KL, editors. Alzheimer's disease, New York:Raven Press; 1994
Tombaugh TN, McIntyre NJ. The Mini-Mental State Examination: a comprehensive review. J Am Geriatr Soc. 1992;40:922-35. [pmid: 1512391].
Torian L, Davidson E, Fulop G, et al. The effect of dementia on acute care in a geriatric medical unit. Int Psychogeriatr. 1992;4:231-9. [pmid: 1477311].
Uhlmann RF, Larson EB. Effect of education on the Mini-Mental State Examination as a screening test for dementia. J Am Geriatr Soc. 1991;39:876-80. [pmid: 1885862].
/U.S. Department of Veterans Affairs. Dementia: guidelines for diagnosis and treatment, 1989 (revised). VA Publication No. IB 18-3.
van der Cammen TJM, van Harskamp F, Stronks DL, et al. Value of the Mini-Mental State Examination and informants' data for the detection of dementia in geriatric outpatients. Psychol Rep. 1992;71:1003-9. [pmid: 1454906].
van Duijn CM, Clayton D, Chandra V, et al. Familial aggregation of Alzheimer's disease and related disorders: a collaborative re-analysis of case-control studies Int J Epidemiol 1991 20(suppl 2):S13 S20 1833349
/Victor M, Adams RD, Collins GH. The Wernicke-Korsakoff syndrome and related neurologic disorders due to alcoholism and malnutrition. 2nd ed. Contemporary neurology series, Philadelphia (PA):FA Davis;1989.
Vitaliano PP, Breen AR, Albert MS, et al. Memory, attention, and functional status in community-residing Alzheimer type dementia patients and optimally healthy aged individuals. J Gerontol. 1984;39:58-64. [pmid: 6690588].
Vitaliano PP, Russo J, Breen AR, et al. Functional decline in the early stages of Alzheimer's disease. J Psychol Aging. 1986;1:41-6.
/Wechsler D. The Wechsler adult intelligence scale revised, New York: The Psychological Corporation;1981
Weinberger M, Samsa GP, Schmader K, et al. Comparing proxy and patients' perceptions of patients' functional status: results from an outpatient geriatric clinic. J Am Geriatr Soc. 1992;40:585-8. [pmid: 1587975].
/Weis K. Personal communication: review of Medicare inpatient claims for 1992. 1992.
/Wells CE. Dementia. 2nd ed, Philadelphia (PA):FA Davis;1977
Welsh K, Butters N, Hughes J, et al. Detection of abnormal memory decline in mild cases of Alzheimer's disease using CERAD neuropsychological measures. Arch Neurol. 1991;48:278-81. [pmid: 2001185].
Welsh KA, Butters N, Hughes JP, et al. Detection and staging of dementia in Alzheimer's disease: use of the neuropsychological measures developed for the Consortium to Establish a Registry for Alzheimer's Disease (CERAD). Arch Neurol. 1992;49:448-52. [pmid: 1580805].
Welsh KA, Butters N, Mohs RC, et al. The Consortium to Establish a Registry for Alzheimer's Disease (CERAD), Part V: a normative study of the neuropsychological battery. Neurology. 1994;44:609-14. [pmid: 8164812].
White H, Davis PB. Cognitive screening tests: an aid in the care of elderly outpatients. J Gen Intern Med. 1990;5:438-45. [pmid: 2231042].
/Whitehouse PJ, editor. Dementia, Philadelphia (PA):FA Davis; 1993
Wild KV, Kaye JA, Oken BS. Early noncognitive change in Alzheimer's disease and healthy aging. J Geriatr Psychiatry Neurol. 1994;7:199-205. [pmid: 7826486].
/Wilder DE, Cross P, Chen J, et al. Operating characteristics of brief screens for dementia in a multicultural population. Am J Geriatr Psychiatry. 1995;3:96-107.
/Wilder DE, Gurland BJ, Chen J, et al. Interpreting subject and informant reports of function in screening for dementia. Int J Geriatr Psychiatry. 1994;9:887-96.
/Williamson J, Stokoe IH, Gray S, et al. Old people at home: their unreported needs. Lancet. 1964;i:1117-20. [pmid: 14132624].
Wisniewski KE, Wisniewski HM, Wen GY. Occurrence of neuropathological changes and dementia of Alzheimer's disease in Down syndrome. Ann Neurol. 1985;7:278-82. [pmid: 3158266].
Wragg RE, Jeste DV. Overview of depression and psychosis in Alzheimer's disease. Am J Psychiatry. 1989;146:577-87. [pmid: 2653053].
/Wurtman RJ, Corkin S, Growdon JH, et al., editors. Advances in neurology, Vol. 51: Alzheimer's disease, New York:Raven Press; 1990.
/Yahr MD, Bergmann KJ, editors. Advances in neurology, Vol. 45. Parkinson's disease, New York: Raven Press; 1986
Yesavage JA. Geriatric Depression Scale. Psychopharmacol Bull. 1988;24:709-11. [pmid: 3249773].
/Yesavage JA. The use of self-rating depression scales in the elderly. In: Poon LW, editor. Handbook for clinical memory assessment of older adults, Washington (DC): American Psychological Association; 1986 p. 213 7
Yesavage JA, Brink TL, Rose TL, et al. Development and validation of a geriatric screening scale: a preliminary report. J Psychiatr Res. 1983;17:37-49. [pmid: 7183759].
Yesavage JA, Brooks JO III, Taylor J, et al. Development of aphasia, apraxia, and agnosia and decline in Alzheimer's disease. Am J Psychiatry. 1993;150:742-7. [pmid: 8480819].
/Zec RF. Neuropsychological functioning in Alzheimer's disease. In: Parks RW, Zec RF, Wilson RS, editors. Neuropsychology of Alzheimer's disease and other dementias, New York: Oxford University Press; 1993 p. 3 80
Zhang M, Katzman R, Salmon D, et al. The prevalence of dementia and Alzheimer's disease in Shanghai, China: impact of age, gender, and education. Ann Neurol. 1990;27:428-37. [pmid: 2353798].