# Executive Summary

Dementia is a syndrome of progressive decline that relentlessly erodes intellectual abilities, causing cognitive and functional deterioration, which leads to impairment of social and occupational functioning. After onset, many patients live a decade or more with advancing debility. Alzheimer's disease and related dementias affect at least 2 million, and possibly as many as 4 million, U.S. residents. The direct and indirect costs to society and affected families are massive: the National Institute on Aging estimates that $90 billion is spent annually for Alzheimer's disease alone. The noneconomic toll is incalculable.

Rates of dementia increase with advancing age. Studies have found consistent evidence for only two other risk factors: family history of dementia and presence of Down syndrome. For Alzheimer's disease, recent research has identified at least three autosomal-dominant forms, all with early-onset symptoms, involving chromosomes 1, 14, and 21. Alleles of the apolipoprotein E 4 gene locus on chromosome 19 have been associated with late-onset Alzheimer's disease.

Alzheimer's disease is the most prevalent dementing disorder in the United States, followed by vascular dementia. Among the other causes of dementia are Parkinson's disease, Huntington's disease, progressive supranuclear palsy, and amyotrophic lateral sclerosis (ALS, often referred to as Lou Gehrig's disease).

The difficulties of correctly diagnosing dementia in its early stages have been documented. In some cases, clinicians diagnose dementia or Alzheimer's disease where it does not exist; in others, a dementing disorder is misdiagnosed or unrecognized. One explanation is a tendency to regard mild deficits of early-stage dementia as inevitable consequences of aging. Despite the acknowledged difficulties of diagnosing early-stage dementia, however, a number of characteristics distinguish it from normal aging and from other syndromes that involve cognitive problems.

Although research on dementia is advancing rapidly, the current medical armamentarium offers no unequivocally effective treatment. Nevertheless, correctly diagnosing dementia in its early stages may have considerable benefits for patients and family members. For example, patients are spared costly and inappropriate treatment related to misdiagnosis, and they and their families have time to prepare for the challenging financial, legal, and medical issues they will face. In addition, diagnosing dementia where it is not present causes distress and also may prevent identification and treatment of other conditions that are responsible for the patient's symptoms.

This Clinical Practice Guideline was developed to improve recognition of early-stage Alzheimer's disease and related dementias by encouraging initial assessment where warranted. Although differential diagnosis is beyond the scope of this guideline, it includes a list of resources for further clinical evaluation once probable dementia has been identified.

This guideline includes two important and useful clinical tools: (a) a table of symptoms that might indicate dementia, which should serve as triggers for an initial assessment, and (b) a sequence of steps to follow in conducting an initial assessment, which can be adapted according to the judgment of individual clinicians and the circumstances of individual patients. The guideline's principal audience is primary care clinicians. In addition, a wide range of other professionals who come in contact with older persons would benefit from awareness of behaviors that could signal the early stages of a dementing disorder.

A three-tier rating system indicates the relative strength of evidence supporting each recommendation. Recommendations strongly supported by data from the scientific literature are indicated by the letter A. The letter B denotes a statement with some scientific support that may be supplemented by expert panel opinion. The letter C is used when data from rigorous scientific studies are unavailable but an appropriate course of action is suggested by expert panel opinion, clinical experience, or both.

This guideline's key points include the following:

- Certain triggers should prompt a clinician to undertake an initial assessment for dementia rather than attribute apparent signs of decline to aging.
- An initial clinical assessment should combine information from a focused history and physical examination, an evaluation of mental and functional status, and reliable informant reports. It should also include assessment for delirium and depression.
- The Functional Activities Questionnaire, an informant-based measure, is particularly useful in the initial assessment for functional impairment.
- Among mental status tests, the Mini-Mental State Examination (MMSE), Blessed Information-Memory-Concentration Test, Blessed Orientation-Memory-Concentration Test, and the Short Test of Mental Status are largely equivalent in discriminative ability for early-stage dementia.
- Clinicians should assess and consider factors such as sensory impairment and physical disability in selection of mental and functional status tests and other confounding factors such as age, educational level, and cultural influences in interpretation of test results.
- When results of both mental and functional status tests are normal and there are no other clinical concerns, reassurance and reassessment in 6 to 12 months are appropriate. No standards are available for reassessment, but 6 to 12 months are suggested. If concerns persist, referral for a second opinion or further clinical evaluation should be considered (refer to resources listed in the guideline).
- When both mental and functional status tests yield findings of abnormality, further clinical evaluation should be conducted.
- When the initial assessment tests show mixed results (mental status impaired but no functional losses, or vice versa), the patient should be referred for neuropsychological, neurological, or psychiatric evaluation, as indicated.
- The progressive nature of the cognitive impairment associated with early-stage dementia makes followup collaboration and continuity of care, for the patient, family, and caregivers, particularly important.

As research on dementia widens knowledge about genetic and other predisposing factors and produces new therapeutic approaches, early recognition and assessment of this devastating disorder will assume even greater importance.