# Acknowledgments

Many people and professional organizations contributed importantly to the development of this Clinical Practice Guideline, from its earliest stages through two review cycles. The consultants, technical advisors, and reviewers listed at the end of this guideline devoted considerable time and effort to this collaborative effort and greatly helped the panel. Several persons helped immeasurably in identifying key issues, compiling relevant literature, and critiquing manuscript drafts of the guideline. These persons were Alan Zonderman, PhD, and Jeffrey Herbst of the Gerontology Research Center, National Institute on Aging; Andrea Pinkham of the University of Iowa; and Gary VandenBos, PhD, executive director of publications and communications, American Psychological Association.

Special acknowledgment goes to Mark Somerfield, PhD, who served with great dedication and competence as project coordinator, overseeing the literature reviews and data coding and extraction for the meta-analyses and without whom this guideline would not have been possible.

The methodological and statistical expertise of Lawrence Hedges, PhD, of the University of Chicago, and Victor Hasselblad, PhD, of Duke University School of Medicine, made possible the meta-analyses that led to several of the guideline's key recommendations.

The Cochairs also thank Barbara J. Shapiro, panel editor, for her superb writing and editing skills and Carole Sherman, panel manager, for her deft supervision of the support services provided by Technical Resources International, Inc. Finally, thanks are due to the Agency for Health Care Policy and Research for its continuing support of the panel's work and its commitment to an evidence-based approach to improving clinical practice.