# Alzheimer's Disease and Related Dementias Guideline Panel

- Paul T. Costa, Jr., PhD (Cochair)
- T. Franklin Williams, MD, FACP (Cochair)
- Marilyn S. Albert, PhD
- Nelson M. Butters, PhD (Deceased)
- Marshal F. Folstein, MD
- Sid Gilman, MD
- Barry J. Gurland, FRCPhys, FRCPsych
- Lisa P. Gwyther, MSW, CCSW, ACSW
- Albert Heyman, MD
- Alfred W. Kaszniak, PhD, ABPP
- Ira R. Katz, MD, PhD
- Linda L. Levy, MA, OTR/L, FAOTA
- Nancy Emerson Lombardo, PhD
- Nancy K. Orr-Rainey, MSG
- Linda R. Phillips, PhD, RN, FAAN
- Martha Storandt, PhD
- Eric G. Tangalos, MD, FACP
- May L. Wykle, PhD, RN, FAAN