# Contributors

## Guideline Panel

Michael C. Fiore, MD, MPH Panel Chair Professor, Department of Medicine Director, Center for Tobacco Research and Intervention University of Wisconsin Medical School Madison, Wisconsin

Dr. Fiore completed medical school at Northwestern University and his internal medicine training at Boston City Hospital. His postgraduate education included a Master of Public Health in Epidemiology from Harvard University. Dr. Fiore received additional training in epidemiology as an Epidemic Intelligence Service (EIS) Officer for the Centers for Disease Control and Prevention, where he completed a Preventive Medicine residency program. Dr. Fiore worked as a medical epidemiologist at the U.S. Office on Smoking and Health, where he contributed to a wide range of national research, educational, and policy projects to control the epidemic of tobacco-related diseases. He is Director of the Center for Tobacco Research and Intervention and a Professor of Medicine at the University of Wisconsin Medical School. At the University of Wisconsin, Dr. Fiore is clinically active, treating patients both in internal medicine and for smoking cessation. He served as Chair of the Agency for Health Care Policy and Research panel that produced the Smoking Cessation Clinical Practice Guideline No. 18. Currently, he serves as Director of a Robert Wood Johnson Foundation National Program Office, Addressing Tobacco in Managed Care.

William C. Bailey, MD, FACP, FCCP Director, Lung Health Center University of Alabama at Birmingham Birmingham, Alabama

Dr. Bailey graduated from Tulane University Medical School in 1965. He is a Diplomate of the American Board of Internal Medicine in both Internal Medicine and Pulmonary Disease, having received certified specialty training in these disciplines at Tulane University Medical Center and Charity Hospital of Louisiana. He has been on the faculty of the University of Alabama at Birmingham (UAB) since 1973. He has practiced medicine, taught, performed research, and been involved in administrative endeavors for his entire career. He has served on the Board of Directors of the American Thoracic Society and also has served on the Council of the National Heart, Lung, and Blood Institute. He has been a member of many editorial review boards of peer-reviewed journals and has served as a frequent scientific reviewer of both scientific articles and peer-reviewed research. He currently holds the Eminent Scholar Chair in Pulmonary Diseases while also being the Director of the UAB Lung Health Center, which is devoted to research in the prevention of lung disease.

Stuart J. Cohen, EdD Canyon Ranch Endowed Chair University of Arizona Prevention Center Tucson, Arizona

Dr. Cohen received his doctorate in Educational Foundations/Psychology from the University of Rochester. For the past 21 years, he has received grants to improve the quality of ambulatory primary care from the National Institutes of Health, the Centers for Disease Control and Prevention, and the Agency for Healthcare Research and Quality. He has published extensively on health promotion and disease prevention interventions directed at both health care providers and patients. His research on methods to improve physician and dentist interventions in smoking cessation showed the importance of having office systems that include reminders for delivery of preventive services.

Sally Faith Dorfman, MD, MSHSA Director, Division of Public Health and Education The Medical Society of the State of NY Lake Success, NY 11042

Dr. Dorfman holds a degree in economics from Harvard/Radcliffe College, a master's degree in Health Services Administration, and an MD from Stanford University. She trained in reproductive health epidemiology as an Epidemic Intelligence Service (EIS) Officer at the Centers for Disease Control and Prevention. She is board certified both in obstetrics and gynecology and in public health/general preventive medicine. Dr. Dorfman has consulted for State, regional, national, and international organizations and was Commissioner of Health for Orange County, New York, from 1988 to 1994. Also, she has published and presented extensively for professional and lay audiences, serves as reviewer for several peer-review journals, and is the recipient of numerous honors and awards. Dr. Dorfman is Director of the Division of Public Health and Education of the Medical Society of the State of New York, and is clinically active as a gynecologist.

Michael G. Goldstein, MD Associate Director, Clinical Education and Research Bayer Institute for Health Care Communication West Haven, Connecticut

Dr. Goldstein is board certified in Internal Medicine and Psychiatry and currently serves as an Associate Director for Clinical Education and Research at the Bayer Institute for Health Care Communication in West Haven, Connecticut. Also, he is an Investigator at the Center for Behavioral and Preventive Medicine at the Miriam Hospital in Providence, Rhode Island, and an Adjunct Professor of Psychiatry and Human Behavior at Brown University School of Medicine. Dr. Goldstein's primary research interests have included developing interventions to enhance the delivery of smoking cessation in primary care settings and testing the efficacy of combined behavioral and pharmacologic interventions for smoking cessation. Dr. Goldstein has served as a member of the Task Force on Nicotine Dependence of the American Psychiatric Association (APA) and also has served on the APA Nicotine Dependence Practice Guideline Panel. He has published extensively in the areas of behavioral medicine, smoking cessation, and health care communication.

Ellen R. Gritz, PhD Professor and Chair Department of Behavioral Science University of Texas M.D. Anderson Cancer Center Houston, Texas

Dr. Gritz is a licensed psychologist and an established leader in cancer prevention and control research. She has published extensively on cigarette smoking behavior, including prevention, cessation, pharmacologic mechanisms, effects on weight, and special issues of women and other high-risk groups (e.g., ethnic minorities, adolescents, and medical populations). Other areas of interest include adherence to cancer control regimens, genetic testing and counseling for hereditary cancers, and quality of life in cancer survivors. Dr. Gritz has served on the National Cancer Policy Board and the Board on Health Promotion and Disease Prevention of the Institute of Medicine.

Richard B. Heyman, MD Former Chair, Committee on Substance Abuse American Academy of Pediatrics Cincinnati, Ohio

A graduate of the Columbia University College of Physicians and Surgeons, Dr. Heyman practices pediatric and adolescent medicine and serves on the faculty of the Division of Adolescent Medicine at Children's Hospital Medical Center in Cincinnati, Ohio. He is a consultant to several adolescent chemical dependency programs and lectures widely in the area of substance abuse. As former chairman of the Committee on Substance Abuse of the American Academy of Pediatrics, he has played a major role in the creation of the Academy's educational programs and materials, as well as the development of policy in the area of alcohol, tobacco, and other drug abuse.

Carlos Roberto Jaén, MD, PhD Associate Professor and Vice-Chair Department of Family Medicine Director, Center for Urban Research in Primary Care State University of New York at Buffalo Buffalo, New York

Dr. Jaén completed medical school at the State University of New York at Buffalo (UB), and his Family Practice Residency and Primary Care Research Fellowship at Case Western Reserve University in Cleveland, Ohio. His graduate education included a PhD in Epidemiology with a concentration in Tobacco Control at Roswell Park Cancer Institute. Dr. Jaén is Director of the Center for Urban Research in Primary Care, Associate Professor and Vice Chair for Research and Development at UB's Department of Family Medicine, and Co-Director of the American Academy of Family Physician's funded Research Center to Evaluate the Value of Family Practice. Dr. Jaén, active in primary care and public health research since 1985, has authored more than 30 publications on smoking cessation and related subjects, such as clinical preventive service delivery and access to care by the urban poor. In 1995, he received a Generalist Physician Faculty Scholar Award by the Robert Wood Johnson Foundation to study asthma among the urban poor in Buffalo. He directs and practices at the Niagara Family Health Center, located in the heart of Buffalo's Puerto Rican community.

Thomas E. Kottke, MD, MSPH Professor of Medicine Consultant, Department of Internal Medicine Division of Cardiovascular Diseases Mayo Clinic Rochester, Minnesota

Dr. Kottke is a clinical cardiologist, epidemiologist, and health services researcher whose primary interest is describing, defining, and overcoming the barriers to the delivery of clinical preventive services. He has published widely on the evidence that clinical support systems are necessary for physicians and other health care professionals to provide preventive services to the patients they serve. Dr. Kottke was a member of the first U.S. Preventive Services Task Force.

Harry A. Lando, PhD Professor, Division of Epidemiology School of Public Health University of Minnesota Minneapolis, Minnesota

Dr. Lando has worked in the field of smoking cessation since 1969. He has published extensively in this area and was a scientific editor of the 1988 Report of the Surgeon General: Nicotine Addiction. His research has focused primarily on the development of effective multicomponent behavioral programs for smoking cessation. He has received numerous awards for his work and has consulted actively with Federal and voluntary agencies, including the National Cancer Institute; the Centers for Disease Control and Prevention; the American Cancer Society; the American Lung Association; the National Heart, Lung, and Blood Institute; and the National Institute on Drug Abuse.

Robert E. Mecklenburg, DDS, MPH Coordinator, Tobacco and Oral Health Initiatives Tobacco Control Research Branch, National Cancer Institute Potomac, Maryland

Dr. Mecklenburg is a Diplomate of the American Board of Dental Public Health. He organizes and manages dental affairs for the National Cancer Institute's Tobacco Control Research Branch and is the tobacco-related research and development advisor for the National Institute of Dental and Craniofacial Research's Office of Science Policy and Analysis. He chairs the National Dental Tobacco-Free Steering Committee and is Vice-Chairman of the Dentistry Against Tobacco Section/Tobacco and Oral Health Committee of the FDI World Dental Federation. He chaired the committee on non-cancer oral effects of tobacco for the first Surgeon General's report on smokeless tobacco. He is the principal author of the NCI publications, Tobacco Effects in the Mouth and How to Help Your Patients Stop Using Tobacco: A Manual for the Oral Health Team. Dr. Mecklenburg has published and lectured widely in the United States and abroad about dental professionals' involvement in the creation of a tobacco-free society.

Patricia Dolan Mullen, DrPH Professor/Behavioral Sciences School of Public Health University of Texas/Houston Houston, Texas

Dr. Mullen is Professor of Behavioral Sciences as well as Training Director and a Senior Investigator at the Center for Health Promotion Research and Development. She has received research grants to study smoking cessation during pregnancy, and she has conducted meta- analyses on this and other topics. She has served on the Expert Panel on the Content of Prenatal Care and on research advisory panels and boards for the National Institutes of Health, the Centers for Disease Control and Prevention, the American Cancer Society, and other national and international organizations. In addition, Dr. Mullen was invited to write the section on smoking cessation during pregnancy for the 2000 Surgeon General's Report on Women and Smoking.

Louise M. Nett, RN, RRT Research Associate, Executive Board Member National Lung Health Education Program Denver, Colorado

Ms. Nett currently is a research associate at the HealthONE Center at Presbyterian/ St. Lukes Hospital and focuses on the early detection of chronic obstructive lung disease and lung cancer, and smoking cessation. Her early work focused on critical care, pulmonary rehabilitation, and oxygen therapy. She is a member of the American Thoracic Society, the American Association for Respiratory Care, the Society for Research on Nicotine and Tobacco, and the American College of Chest Physicians. Ms. Nett has published and taught extensively on the mentioned topics, and she is co-editor of the newsletter Lung Cancer Frontiers. She has received numerous awards and has consulted and lectured internationally.

Lawrence Robinson, MD, MPH Deputy Health Commissioner Philadelphia Department of Public Health Health Promotion/Disease Prevention Philadelphia, Pennsylvania

A graduate of Harvard College, Dr. Robinson received his MD from the University of Pennsylvania School of Medicine. He received his MPH and completed a residency in preventive medicine at Johns Hopkins University. He was a resident and faculty member at Rush and Columbia University while performing his internal medicine training. As Deputy Commissioner for Health Promotion/Disease Prevention for the Philadelphia Department of Public Health, Dr. Robinson is responsible for the development, planning, implementation, and evaluation of various programs delivering medical, chronic disease prevention, and health education services. Local anti- tobacco projects include banning vending machines, assisting the county jail move to a smoke-free environment, Nicotrol Patch replacement, and the American Cancer Society Fresh Start Program. This train-the-trainer program was provided to the mentally ill and other targeted populations. Dr. Robinson also is a board member of the Pennsylvania American Cancer Society and Chairman of the State Tobacco Core Team. He is a member of various groups, organizations, and agencies in the community working on issues such as the State Tobacco Settlement (No Butts/Do the Right Thing) and smoking prevention for youth and special populations such as pregnant women.

Maxine L. Stitzer, PhD Professor, Department of Psychiatry and Behavioral Sciences Behavioral Biology Research Center Johns Hopkins/Bayview Medical Center Baltimore, Maryland

Dr. Stitzer received her PhD in Psychology and training in psychopharmacology from the University of Michigan. At Johns Hopkins University, she has developed a varied and extensive grant-supported research program focusing on both pharmacological and behavioral approaches to the treatment of substance abuse. Her many publications reflect active research interests in both illicit drug abuse and tobacco dependence. She has been president of the Division on Psychopharmacology and Substance Abuse of the American Psychological Association and has served on the Board of Directors of the College on Problems of Drug Dependence.

Anthony C. Tommasello, MS Director, Office of Substance Abuse Studies University of Maryland School of Pharmacy Baltimore, Maryland

Mr. Tommasello, a pharmacist, is an Associate Professor of Clinical Pharmacy at the University of Maryland School of Pharmacy, and Director, Office of Substance Abuse Studies, which he founded. He has worked in the addiction field since 1973 and acquired advanced degrees in both pharmacology and epidemiology, specializing in drug abuse and addiction. He is active in clinical research and treatment in addictions and has created educational programs that have served as national models for pharmacists and other health and human service providers. He is the president of the Maryland Pharmacists' Rehabilitation Committee, which provides advocacy and treatment access for impaired pharmacists. He has published in the areas of general principles of assessment and treatment, methadone maintenance care, and adolescent drug abuse and addiction. Mr. Tommasello is a PhD candidate in Policy Sciences at University of Maryland--Baltimore Campus, where his focus has been on health policy analysis. His dissertation is entitled "The Effects of State Policies on Addiction Intervention in the Health Professions: The Case of Pharmacy."

Louise Villejo, MPH, CHES Director, Patient Education Office Office of Public Affairs University of Texas M.D. Anderson Cancer Center Houston, Texas

As the Director of the Patient Education Office at the M.D. Anderson Cancer Center, Ms. Villejo is responsible for the design, implementation, evaluation, and management of institution-wide patient and family education programs. She has designed and implemented Patient/Family Learning Centers as well as award-winning disease specific patient education programs and produced more than 100 patient education print materials and videotapes. For the past 10 years, she has served on the National Cancer Institute's Advisory Boards and Patient Education Network's Steering Committee as well as on numerous other Federal and private advisory and planning boards and committees. Ms. Villejo's publications include articles on cancer patient education and cultural diversity in health care.

Mary Ellen Wewers, PhD, MPH, RN Professor College of Nursing Ohio State University Columbus, Ohio

Dr. Wewers, an Adult Nurse Practitioner, received her PhD in Nursing from the University of Maryland at Baltimore and an MPH from Harvard University. She has been funded by the National Institutes of Health (NIH) to investigate reinforcement for nicotine in both human and animal models of dependence. Her current NIH-funded research examines nurse-managed tobacco cessation interventions in underserved groups. Dr. Wewers is past Chair of the Nursing Assembly of the American Thoracic Society and a past member of the American Thoracic Society's Board of Directors. She serves as co-director of the Nursing Center for Tobacco Intervention at Ohio State University.

### Senior Consultants

- Timothy Baker, PhD
- Senior Scientific Consultant
- Professor, Department of Psychology
- Associate Director, Center for Tobacco Research and Intervention
- University of Wisconsin Medical School
- Madison, Wisconsin

- Victor Hasselblad, PhD
- Statistical Methodologist
- Duke Clinical Research Institute
- Duke University
- Durham, North Carolina

### Other Consultants

- Marc Manley, MD, MPH
- Executive Director, Center for Tobacco Reduction and Health Improvement
- Blue Cross and Blue Shield of Minnesota
- St. Paul, Minnesota

- John Mullahy, PhD
- Professor, Department of Preventive Medicine
- Department of Economics
- University of Wisconsin, Madison
- Madison, Wisconsin

- David L. Schriger, MD, MPH
- Associate Professor , UCLA School of Medicine
- UCLA Emergency Medicine Center
- Los Angeles, California

- David W. Wetter, PhD
- Associate Scientific Advisor
- Center for Health Studies
- Seattle, Washington

### Project Staff

- Brion J. Fox, JD
- Project Director
- Center for Tobacco Research and Intervention
- University of Wisconsin Medical School
- Madison, Wisconsin

- Bridget C. Whisler
- Project Manager
- Center for Tobacco Research and Intervention
- University of Wisconsin Medical School
- Madison, Wisconsin

- Sam Welsch
- Senior Research Associate
- Center for Tobacco Research and Intervention
- University of Wisconsin Medical School
- Madison, Wisconsin

- Megan Piper, MA
- Senior Research Associate
- Center for Tobacco Research and Intervention
- University of Wisconsin Medical School
- Madison, Wisconsin

- Silvia Kang
- Project Research Associate
- Center for Tobacco Research and Intervention
- University of Wisconsin Medical School
- Madison, Wisconsin

- Rebecca Boex
- Project Research Associate
- Center for Tobacco Research and Intervention
- University of Wisconsin Medical School
- Madison, Wisconsin

### Additional Project Staff

- Kylee Carolfi
- Mara Cvejic
- Karin Christoph
- Jackie Grove
- Jason Horowitz
- Ann Schensky
- Melanie Schrank
- Natalie Syty
- Carolina Ugaz
- Mark Zehner
- Center for Tobacco Research and Intervention
- University of Wisconsin Medical School
- Madison, Wisconsin

### Guideline Consortium Representatives

#### Agency for Healthcare Research and Quality Rockville, Maryland

- Douglas B. Kamerow, MD, MPH
- Director
- Center for Practice and Technology Assessment

- Ernestine W. Murray, RN, MAS
- Panel Project Officer
- Center for Practice and Technology Assessment

- Harriett V. Bennett
- Public Affairs Specialist
- Office of Health Care Information

- Sandra Katz Cummings
- Managing Editor
- Office of Health Care Information

### Centers for Disease Control and Prevention Atlanta, Georgia

- Corinne G. Husten, MD, MPH
- Medical Officer
- Office on Smoking and Health
- National Center for Chronic Disease Prevention and Health Promotion

- Cathy Melvin, PhD, MPH
- Chief, Program Services and Development Branch
- Division of Reproductive Health
- National Center for Chronic Disease Prevention and Health Promotion

### National Cancer Institute Bethesda, Maryland

- Glen D. Morgan, PhD
- Tobacco Control Research Branch
- Rockville, Maryland

### National Heart, Lung, and Blood Institute Bethesda, Maryland

- Glen Bennett, MPH
- Coordinator, Advance Technologies Applications in Health Education Programs
- Office of Prevention, Education, and Control

### National Institute on Drug Abuse Rockville, Maryland

- Stephen Heishman, PhD
- Senior Investigator
- Clinical Pharmacology and Therapeutics Branch
- Baltimore, Maryland

### The Robert Wood Johnson Foundation Princeton, New Jersey

- C. Tracy Orleans, PhD
- Senior Scientist

### Center for Tobacco Research and Intervention University of Wisconsin Medical School Madison, Wisconsin

- Douglas Jorenby, PhD
- University of Wisconsin Medical School

### Contract Support

#### The Scientific Consulting Group, Inc. Gaithersburg, Maryland

- Marcia Feinleib
- Project Director

- Maria Osvald
- Managing Editor

- Mark Searles
- Production Manager

### Article Reviewers

- Brion J. Fox, JD
- Rebecca Boex
- Mara Cvejic
- Silvia Kang
- Natalie Syty
- Carolina Ugaz
- Sam Welsch
- Center for Tobacco Research and Intervention
- University of Wisconsin Medical School
- Madison, Wisconsin

### Peer Reviewers

- Jasjits S. Ahluwalia, MD, MPH MS
- Vice Chair and Director of Research
- Preventive Medicine
- University of Kansas Medical Center
- Kansas City, Missouri

- Frederic Bass, MD, DSC
- Director, BC Doctors Stop-Smoking
- Program and Specialist in Clinical
- Preventive Health Care
- Vancouver, BC Canada

- Terry L. Bazzarre, PhD
- Staff Scientist
- American Heart Association
- Dallas, Texas

- Michele Bloch, MD, PhD
- Medical Officer
- Tobacco Control Research Branch
- National Cancer Institute
- Rockville, Maryland

- Alan Blum, MD
- Founder and Chairman
- Doctors Ought to Care
- DOC Tobacco Archive and International Resource Center
- Houston, Texas

- Thomas H. Brandon, PhD
- Director, Tobacco Research
- H. Lee Moffitt Cancer Center Institute
- Tampa, Florida

- Joan Brewster, PhD
- Assistant Professor
- Department of Public Health Sciences
- University of Toronto
- Toronto, Ontario, Canada

- David M. Burns, MD
- Professor of Medicine
- Division of Pulmonary and Critical Care
- University of California-San Diego School of Medicine
- San Diego, California

- Janet Chapin, RN, MPH
- Director, Division of Women's Health Issues
- The American College of Obstetricians and Gynecologists
- Washington, DC

- Helene Cole, MD
- Senior Editor, JAMA
- American Medical Association
- Chicago, Illinois

- William A. Corrigall, PhD
- Research Scientist
- Center for Addiction and Mental Health
- Nicotine and Tobacco Dependence Program
- Toronto, Ontario, Canada

- David R. Coultas, MD
- Professor and Chief, Epidemiology and Preventive Medicine
- University of New Mexico Health Sciences Center
- Department of Internal Medicine
- Epidemiology and Cancer Control Program
- Albuquerque, New Mexico

- Susan J. Curry, PhD
- Director, Center for Health Studies
- Group Health Cooperative
- Seattle, Washington

- Ronald M. Davis
- Director, Center for Health Promotion
- Henry Ford Health System
- Detroit, Michigan

- Jane Delgado, PhD, MS
- President and CEO
- National Coalition of Hispanic Health and Human Services
- Washington, DC

- Karl O. Fagerstrom, PhD
- Director
- Pharmacy
- S-25109 Helsingborg, Sweden

- Sam P. Giordano, MBA, RRT
- Executive Director
- American Association for Respiratory Care
- Dallas, Texas

- Elbert D. Glover, PhD
- Professor, Department of Behavioral Medicine and Psychiatry
- West Virginia School of Medicine
- Mary Babb Randolph Cancer Center
- Morgantown, West Virginia

- Thomas J. Glynn, PhD
- Director, Cancer Science and Trends
- American Cancer Society
- Washington, DC

- Sharon M. Hall, PhD
- Professor and Vice-Chair, Psychiatry Department
- University of California-San Francisco
- San Francisco, California

- Dorothy K. Hatsukami, PhD
- Professor and Consulting Psychologist
- Department of Psychiatry
- University of Minnesota
- Minneapolis, Minnesota

- Jack E. Henningfield, PhD
- Vice President
- Research and Health Policy
- Pinney Associates
- Bethesda, Maryland

- Thomas P. Houston, MD
- Director
- Department of Preventive Medicine
- and Environmental Health
- American Medical Association
- Chicago, Illinois

- John R. Hughes, MD
- Professor, Department of Psychiatry
- University of Vermont
- Burlington, Vermont

- Martin J. Jarvis, MPhD
- Imperial Cancer Research Fund
- Department of Epidemiology and Public Health
- University College London
- London, England

- J. Andrew Johnston, PharmD
- Head, Psychiatry Clinical Development
- Glaxo Wellcome, Inc.
- Research Triangle Park, North Carolina

- Nancy Kaufman, MS, RN
- Vice President
- The Robert Wood Johnson Foundation
- Princeton, New Jersey

- Robert C. Klesges, PhD
- Executive Director
- University of Memphis Prevention Center
- Memphis, Tennessee

- Connie L. Kohler, DrPH
- Assistant Professor
- School of Public Health
- University of Alabama at Birmingham
- Birmingham, Alabama

- B. Wain Kong, MD
- Executive Director
- Association of Black Cardiologists
- Atlanta, Georgia

- Eva Kralikova, MD, PhD
- First Faculty of Medicine
- Charles University
- Prague, Czech Republic

- Edward Lichtenstein, PhD
- Research Scientist
- Oregon Research Institute
- Eugene, Oregon

- Kathleen Lindell, RN, MSN
- Program Director
- The PENN Quit Smoking Program
- University of Pennsylvania
- Philadelphia, Pennsylvania

- Daniel R. Longo, ScD
- Professor, Family and Community Medicine
- University of Missouri-Columbia
- Columbia, Missouri

- Jerold R. Mande
- Deputy Assistant Secretary
- Occupational Safety and Health Administration
- U.S. Department of Labor
- Washington, DC

- Timothy McAfee, MD, MPH
- Director, Center for Health Promotion and Disease Prevention
- Group Health Cooperative of Puget Sound
- Seattle, Washington

- Daniel E. McGoldrick, MA
- Director, Research
- Campaign for Tobacco-Free Kids
- Washington, DC

- Norman Montalto, DO
- Associate Professor, Family Medicine
- Director, Freedom from Tobacco Program
- Robert C. Byrd Health Sciences Center
- West Virginia University/Charleston Division
- Charleston, West Virginia

- Mildred S. Morse, JD
- Director, National Tobacco Independence Campaign
- Morse Enterprises, Inc.
- Silver Spring, Maryland

- Judith K. Ockene, PhD, MEd
- Professor of Medicine
- Director, Division of Preventive and Behavioral Medicine
- University of Massachusetts Medical School
- Worcester, Massachusetts

- Debra J. Ossip-Klein, PhD
- Research Associate Professor of Community and Preventive Medicine and Oncology
- Director, Smoking Research Program
- University of Rochester Cancer Center
- Rochester, New York

- Pamela H. Payne
- Project Director, Tobacco ROAD
- National Medical Association
- Washington, DC

- Thomas A. Pearson, MD, MPH, PhD
- Professor and Chair of Community and Preventive Medicine
- University of Rochester
- Rochester, New York

- Kenneth A. Perkins, PhD
- Professor of Psychiatry
- Western Psychiatric Institute and Clinic
- University of Pittsburgh
- Pittsburgh, Pennsylvania

- John P. Pierce, PhD
- Sam M. Walton Professor for Cancer Research
- UCSD Cancer Center
- University of California-San Diego
- San Diego, California

- Donald Pine, MD
- Family Practice Physician
- Health System Minnesota
- Minneapolis, Minnesota

- Patricia G. Porter, RN, MPH, CHES
- Director, Project Development
- Integrating Medicine and Public Health Program
- UCSF Institute for Health and Aging
- California Department of Health Services
- San Francisco, California

- Stephen I. Rennard, MD
- Professor of Medicine
- University of Nebraska Medical Center
- Omaha, Nebraska

- Nancy A. Rigotti, MD
- Director, Tobacco Research and Treatment Center
- Harvard Medical School
- Massachusetts General Hospital
- Boston, Massachusetts

- Barbara K. Rimer, DrPH
- Division of Cancer Control and Population Sciences
- National Cancer Institute
- Rockville, Maryland

- William A. Robinson, MD, MPH
- Director, Center for Quality
- Chief Medical Officer
- Health Resources and Services Administration
- Department of Health and Human Services
- Rockville, Maryland

- Jacqueline Royce, PhD
- President, Royce Associates
- Atlantic Highlands, New Jersey

- Helen H. Schauffler, PhD, MSPH
- Associate Professor and Director
- Center for Health and Public Policy Studies
- University of California-Berkeley
- School of Public Health
- Berkeley, California

- Manuel Schydlower, MD
- Professor of Pediatrics
- Assistant Dean for Medical Education
- Texas Tech Health Sciences Center
- El Paso, Texas

- Roger Secker-Walker, MB, FRCP
- Professor Emeritus
- University of Vermont
- Burlington, Vermont

- Herbert Severson, PhD
- Senior Research Scientist
- Oregon Research Institute
- Eugene, Oregon

- Saul Shiffman, PhD
- Professor of Psychology
- University of Pittsburgh
- Pittsburgh, Pennsylvania

- John Slade, MD
- Professor
- Department of Environment and Community Medicine
- The Robert Wood Johnson Medical School
- New Brunswick, New Jersey

- Leif I. Solberg, MD
- Director for Care Improvement Research
- Group Health Foundation
- Minneapolis, Minnesota

- Anne N. Thorndike, MD
- Instructor of Medicine
- Harvard Medical School and Massachusetts General Hospital
- Boston, Massachusetts

- Phillip K. Tonnesen, MD
- Chief of Department
- Department of Pulmonary Disease
- Gentofte Amts Hospital
- Copenhagen, Denmark

- Kenneth E. Warner, PhD
- Richard D. Remington Collegiate Professor
- University of Michigan School of Public Health
- Ann Arbor, Michigan

- Barbara Widmar, MA
- Manager, Health Education Department
- American Academy of Family Physicians
- Leawood, Kansas

- Richard Windsor, MS, MPH, PhD
- Research Professor
- Department of Human Studies
- University of Alabama at Birmingham
- Birmingham, Alabama

- Douglas Ziedonis, MD, MPH
- Director, Division of Addiction Psychiatry
- Department of Psychiatry
- The Robert Wood Johnson Medical School
- Piscataway, New Jersey