# References

1 Centers for Disease Control and Prevention. Perspectives in disease prevention and health promotion. Smoking-attributable mortality and years of potential life lost -- United States, 1984. MMWR Morb Mortal Wkly Rep. 1997;46(20):444-51. [pmid: 9182206].
2 US Department of Health and Human Services. The health benefits of smoking cessation: A report of the Surgeon General. Atlanta (GA): US Department of Health and Human Services. Public Health Service, Centers for Disease Control, Center for Chronic Disease Prevention and Health Promotion, Office of Smoking and Health. DHHS Publication No. (CDC) 90-8416, 1990.
3 Centers for Disease Control and Prevention. Health objectives for the nation cigarette smoking among adults—United States, 1993. MMWR Morb Mortal Wkly Rep. 1994;43(50):925-30. [pmid: 7990796].
4 Centers for Disease Control and Prevention. Cigarette smoking among adults—United States, 1995. MMWR Morb Mortal Wkly Rep. 1997;46(51):1217-20. [pmid: 9427212].
5 Centers for Disease Control and Prevention. Cigarette smoking among adults—United States, 1997. MMWR Morb Mortal Wkly Rep. 1999;48(43):993-6. [pmid: 10577493].
6 Centers for Disease Control and Prevention. Tobacco use among high school students—United States, 1997. MMWR Morb Mortal Wkly Rep. 1998;47(12):229-233. [pmid: 9572629].
7 Centers for Disease Control and Prevention. Incidence of initiation of cigarette smoking—United States, 1965-1996. MMWR Morb Mortal Wkly Rep. 1998;47(39):837-40. [pmid: 9780240].
8 Gilpin E, Choi WS, Berry C, Pierce JP. How many adolescents start smoking each day in the United States?. J Adolesc Health. 1999;25:248-55. [pmid: 10505842].
9 Miller LS, Zhang X, Rice DP, Max W. State estimates of total medical expenditures attributable to cigarette smoking, 1993. Public Health Rep. 1998;113(5):447-58. [pmid: 9769770].
10 Centers for Disease Control and Prevention. Medical care expenditures attributable to cigarette smoking—United States, 1993. MMWR. 1994;43(26):469-72. [pmid: 8007931].
11 Thorndike AN, Rigotti NA, Stafford RS, Singer DE. National patterns in the treatment of smokers by physicians. JAMA. 1998;279(8):604-8. [pmid: 9486755].
12 Fiore MC, Jorenby DE, Schensky AE, Smith SS, Bauer RR, Baker TB. Smoking status as the new vital sign: effect on assessment and intervention in patients who smoke. Mayo Clin Proc. 1995;70(3):209-13. [pmid: 7861807].
13 Glynn TJ, Manley MW, Pechacek TF. Physician-initiated smoking cessation program: the National Cancer Institute trials. Prog Clin Biol Res. 1990;339:11-25. [pmid: 2118257].
14 Jaen C, Stange K, Tumiel L, Nutting P. Missed opportunities for prevention: smoking cessation advice and the competing demands of practice. J Fam Pract. 1997;45(4):348-54. [pmid: 9343057].
15 Russell MA, Wilson C, Taylor C, Baker CD. Effect of general practitioners' advice against smoking. BMJ. 1979;2(6184):231-5. [pmid: 476401].
16 Lightwood JM, Glantz SA. Short-term economic and health benefits of smoking cessation: myocardial infarction and stroke. Circulation. 1997;96(4):1089-96. [pmid: 9286934].
17 US Department of Health and Human Services. Public Health Service. Healthy People 2000: national health promotion and disease prevention objectives. Washington (DC): US Department of Health and Human Services, Public Health Service. DHHS Publication No.(PHS) 91-50212. 1991.
18 Orleans CT. Treating nicotine dependence in medical settings: a stepped-care model. In: Orleans CT, Slade J, editors. Nicotine addiction: principles and management. New York: Oxford University Press, 1993.
19 McBride PE, Plane MB, Underbakke G, Brown RL, Solberg LI. Smoking screening and management in primary care practices. Arch Fam Med. 1997;6(2):165-72. [pmid: 9075453].
20 Thorndike A, Ferris T, Stafford R, Rigotti N. Rates of US physicians counseling adolescents about smoking. Journal of the National Cancer Institute. 1999;91(21):1857-62. [pmid: 10547392].
21 Cabana M, Rand C, Powe N, Wu A, et al. Why don't physicians follow clinical practice guidelines?. JAMA. 1999;282(15):1458-64. [pmid: 10535437].
22 Jaen C, Crabtree B, Zyzanski S, Goodwin M, Stange K. Making time for smoking cessation counseling. J Fam Pract. 1998;46(5):425-8. [pmid: 9598001].
23 Slade J. Cessation: it's time to retire the term. SRNT Newsletter. 1999;5(3):1-4.
24 Jones H, Garrett B, Griffiths R. Subjective and physiological effects of intravenous nicotine and cocaine in cigarette smoking cocaine abusers. J Pharmacol Exp Ther. 1999;288(1):188-97. [pmid: 9862770].
25 US Department of Health and Human Services. The health consequences of smoking: nicotine addiction. A report of the Surgeon General. Atlanta (GA): US Department of Health and Human Services. Public Health Service, Centers for Disease Control, Center for Chronic Disease Prevention and Health Promotion, Office of Smoking and Health. DHHS Publication No. (PHS) (CDC) 88-8406. 1988.
26 American Psychiatric Association. Practice guideline for the treatment of patients with nicotine dependence. Am J Psychiatry. 1996;153(10 (Suppl)):S1-S31. [pmid: 8831466].
27 American Medical Association. American Medical Association guidelines for the diagnosis and treatment of nicotine dependence: how to help patients stop smoking. Washington DC: American Medical Association, 1994.
28 British Thoracic Society. Smoking cessation guidelines and their cost-effectiveness. Thorax. 1998;53(Suppl 5, part 1):S1-S38. [pmid: 10226676].
29 The Cochrane Collaboration. Cochrane Database of Systematic Reviews. The Cochrane Library 1999; (4).
30 Centers for Disease Control and Prevention. Smoking cessation during previous year among adults—United States, 1990 and 1991. MMWR Morb Mortal Wkly Rep. 1993;42(26):504-7. [pmid: 8515740].
31 Hatziandreu EJ, Pierce JP, Lefkopoulou M, Fiore MC, Mills SL, Novotny TE, et al. Quitting smoking in the United States in 1986. J Natl Cancer Inst. 1990;82(17):1402-6. [pmid: 2388290].
32 Fiore MC, Baker TB. Smoking cessation treatment and the good doctor club [editorial]. Am J Public Health. 1995;85(2):161-3. [pmid: 7856771].
33 Mezzich J, Kraemer H, Worthington D, Coffman G. Assessment of agreement among several raters formulating multiple diagnoses. J Psychiatr Res. 1981;16:29-39. [pmid: 7205698].
34 Fleiss J. Statistical methods for rates and proportions. New York: Wiley, 1981.
35 Kendrick JS, Zahniser SC, Miller N, Salas N, Stine J, Gargiullo PM, et al. Integrating smoking cessation into routine public prenatal care: the Smoking Cessation in Pregnancy project. Am J Public Health. 1995;85(2):217-22. [pmid: 7856781].
36 Walsh RA, Redman S, Adamson L. The accuracy of self-report of smoking status in pregnant women. Addict Behav. 1996;21(5):675-9. [pmid: 8876767].
37 Windsor RA, Lowe JB, Perkins LL, Smith-Yoder D, Artz L, Crawford M, et al. Health education for pregnant smokers: its behavioral impact and cost benefit. Am J Public Health. 1993;83(2):201-6. [pmid: 8427323].
38 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
39 Hosmer DW, Lemeshow S. Applied logistic regression. New York: Wiley, 1989.
40 Eddy DM. FAST*PRO software for meta-analysis by the confidence profile method [manual for software]. San Diego (CA): Academic Press, 1992.
41 Centers for Disease Control and Prevention. Physician and other health care professional counseling of smokers to quit—United States, 1991. MMWR Morb Mortal Wkly Rep. 1993;42(44):854-7. [pmid: 8232167].
42 Hayward RA, Meetz HK, Shapiro MF, Freeman HE. Utilization of dental services: 1986 patterns and trends. J Public Health Dent. 1989;49(3):147-52. [pmid: 2769632].
43 Tomar SL, Husten CG, Manley MW. Do dentists and physicians advise tobacco users to quit?. J Am Dent Assoc. 1996;127(2):259-65. [pmid: 8682997].
44 National Cancer Institute. Tobacco and the clinician: interventions for medical and dental practice. Monogr Natl Cancer Inst 5, 1-22. NIH Publication No. 94-3693. 1994.
45 Ockene JK. Smoking intervention: The expanding role of the physician. Am J Public Health. 1987;77(7):782-3. [pmid: 3592029].
46 Pederson LL, Baskerville JC, Wanklin JM. Multivariate statistical models for predicting change in smoking behavior following physician advice to quit smoking. Prev Med. 1982;11(5):536-49. [pmid: 7156062].
47 Woller SC, Smith SS, Piasecki TM, Jorenby DE, Helberg CP, Love RR, et al. Are clinicians intervening with their patients who smoke? A "real-world" assessment of 45 clinics in the upper Midwest. WMJ. 1995;94(5):266-72. [pmid: 7618339].
48 Goldstein MG, Niaura R, Willey-Lessne C, DePue J, Eaton C, Rakowski W, et al. Physicians counseling smokers. A population-based survey of patients' perceptions of health care provider-delivered smoking cessation interventions. Arch Intern Med. 1997;157(12):1313-9. [pmid: 9201005].
49 Stange K, Zyzanski S, Jaen C, et al. Illuminating the black box: a description of 4454 patient visits of 138 family physicians. J Fam Pract. 1998;46(5):377-89. [pmid: 9597995].
50 Gilchrist V, Miller RS, Gillanders WR, Scheid DC, Logue EE, Iverson DC, et al. Does family practice at residency teaching sites reflect community practice?. J Fam Pract. 1993;37(6):555-63. [pmid: 8245806].
51 Lichtenstein E, Hollis J. Patient referral to a smoking cessation program: who follows through?. J Fam Pract. 1992;34(6):739-44. [pmid: 1593248].
52 Glynn TJ, Manley MW. How to help your patients stop smoking: a National Cancer Institute manual for physicians. Bethesda, MD: NIH Publication No. 89-3064. 1989.
53 Kottke TE, Solberg LI, Brekke ML. Beyond efficacy testing: introducing preventive cardiology into primary care. Am J Prev Med. 1990;6(2 Suppl):77-83. [pmid: 2200453].
54 Mecklenburg RE, Christen AG, Gerbert B, Gift MC. How to help your patients stop using tobacco: a National Cancer Institute manual for the oral health team 1990. US DHHS Public Health Service, National Institutes of Health, National Cancer Institute. NIH Publication No. 91-3191, 1991.
55 Rundmo T, Smedslund G, Gotestam KG. Motivation for smoking cessation among the Norwegian public. Addict Behav. 1997;22(3):377-86. [pmid: 9183507].
56 Colby SM, Barnett NP, Monti PM, Rohsenow DJ, et al. Brief motivational interviewing in a hospital setting for adolescent smoking: a preliminary study. J Consult Clin Psychol. 1998;66(3):574-8. [pmid: 9642898].
57 Miller W, Rolnick S. Motivational interviewing: preparing people to change addictive behavior. New York: Guilford, 1991.
58 Prochaska J, Goldstein MG. Process of smoking cessation. Implications for clinicians. Clin Chest Med. 1991;12(4):727-35. [pmid: 1747990].
59 Westman EC, Behm FM, Simel DL, Rose JE. Smoking behavior on the first day of a quit attempt predicts long-term abstinence. Arch Intern Med. 1997;157(3):335-40. [pmid: 9040302].
60 Zhu SH, Stretch V, Balabanis M, Rosbrook B, Sadler G, Pierce JP. Telephone counseling for smoking cessation: effects of single-session and multiple-session interventions. J Consult Clin Psychol. 1996;64(1):202-11. [pmid: 8907100].
61 Brandon TH, Tiffany ST, Obremski K, Baker TB. Postcessation cigarette use: the process of relapse. Addict Behav. 1990;15:105-14. [pmid: 2343783].
62 Carroll KM. Relapse prevention as a psychosocial treatment: A review of controlled clinical trials. Exp Clin Psychopharmacol. 1996;4(1):46-54.
63 US Department of Health and Human Services. Preventing tobacco use among young people. A report of the Surgeon General. Atlanta (GA): US Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 1994.
64 Cromwell J, Bartosch WJ, Fiore MC, Hasselblad V, Baker T. Cost-effectiveness of the clinical practice recommendations in the AHCPR Guideline for Smoking Cessation. Agency for Health Care Policy and Research. JAMA. 1997;278(21):1759-66. [pmid: 9388153].
65 Fiore MC, Novotny TE, Pierce JP, Giovino GA, Hatziandreu EJ, Newcomb PA, et al. Methods used to quit smoking in the United States. Do cessation programs help? [published erratum appears in JAMA 1991 Jan 16; 265(3): 358]. JAMA. 1990;263(20):2760-5. [pmid: 2271019].
66 Curry SJ, Grothaus LC, McAfee T, Pabiniak C. Use and cost effectiveness of smoking-cessation services under four insurance plans in a health maintenance organization. N Engl J Med. 1998;339(10):673-9. [pmid: 9725926].
67 Aakko E, Piasecki TM, Remington P, Fiore MC. Smoking cessation services offered by health insurance plans for Wisconsin State Employees. WMJ. 1999;98:14-8. [pmid: 10050148].
68 Group Health Association of America. HMO industry profile: 1993 edition. Washington DC: Group Health Association of America, 1993.
69 Barker D, Orleans CT, Schauffler H. Tobacco treatment services should be covered under Medicaid (letter). Tob Control. 1998;7(1). [pmid: 9706761].
70 McPhillips-Tangum C. Results from the first annual survey on Addressing Tobacco in Managed Care. Tob Control. 1998;7(Suppl):S11-S14. [pmid: 10093188].
71 Cummings SR, Rubin SM, Oster G. The cost-effectiveness of counseling smokers to quit. JAMA. 1989;261(1):75-9. [pmid: 2491762].
72 Tengs T, Adams M, Pliskin J, Safran D, Seigel J, Weinstein M, et al. Five-hundred life-saving interventions and their cost effectiveness. Risk Anal. 1995;15(3):369-90. [pmid: 7604170].
73 US Department of Health and Human Services. Healthy People 2000: National health promotion and disease prevention objectives. Washington DC: US Department of Health and Human Service, Public Health Service, 1995.
74 US Department of Health and Human Services. Healthy People 2010 (Conference Edition, in Two Volumes). Washington DC. 2000.
75 Eddy DM. The economics of cancer prevention and detection: getting more for less. Cancer. 1981;47(5 Suppl):1200-9. [pmid: 6786726].
76 Eddy DM. Setting priorities for cancer control programs. J Natl Cancer Inst. 1986;76(2):187-99. [pmid: 3080634].
77 Oster G, Huse DM, Delea TE, Colditz GA. Cost-effectiveness of nicotine gum as an adjunct to physician's advice against cigarette smoking. JAMA. 1986;256(10):1315-8. [pmid: 3091857].
78 Eddy DM. David Eddy ranks the tests. Harv Health Lett 1992; 11.
79 Jackson SE, Cheneweth D, Glover ED, Holbert D, White D. Study indicates smoking cessation improves workplace absenteeism rate. Occup Health Saf. 1989;58(13):13, 15-6, 18. [pmid: 2601927].
80 Kristein M. How much can business expect to profit from smoking cessation?. Prev Med. 1993;12(2):358-81. [pmid: 6410369].
81 Ahluwalia JS. Reaching the medically underserved with the AHCPR guideline. Tob Control. 1997;6(Suppl 1):S29-S32. [pmid: 9396118].
82 Ahluwalia J, Gibson C, Kenney R, Wallace D, Resnicow K. Smoking status as a vital sign. J Gen Intern Med. 1999;14(7):402-8. [pmid: 10417597].
83 Chang HC, Zimmerman LH, Beck JM. Impact of chart reminders on smoking cessation practices of pulmonary physicians. Am J Respir Crit Care Med. 1995;152(3):984-7. [pmid: 7663814].
84 Robinson MD, Laurent SL, Little JM, Jr. Including smoking status as a new vital sign: it works!. J Fam Pract. 1995;40(6):556-61. [pmid: 7775909].
85 Yarnall KS, Rimer BK, Hynes D, Watson G, Lyna PR, Woods-Powell CT, et al. Computerized prompts for cancer screening in a community health center. J Am Board Fam Pract. 1998;11(2):96-104. [pmid: 9542701].
86 Dijkstra A, de Vries H, Roijackers J, van Breukelen G. Tailored interventions to communicate stage-matched information to smokers in different motivational stages. J Consult Clin Psychol. 1998;66(3):549-57. [pmid: 9642894].
87 Velicer W, Prochaska JO, Fava J, Laforge R, Rossi JS. Interactive versus noninteractive interventions and dose-response relationships for stage-matched smoking cessation programs in a managed care setting. Health Psychol. 1999;18(1):21-8. [pmid: 9925042].
88 Gilbert D, Crauthers D, Mooney D, McClernon F, Jensen R. Effects of monetary contingencies on smoking relapse: influences of trait depression, personality, and habitual nicotine intake. Exp Clin Psychopharmacol. 1999;7(2):174-81. [pmid: 10340157].
89 Jaen CR, Stange KC, Nutting PA. Competing demands of primary care: a model for the delivery of clinical preventive services. J Fam Pract. 1994;38(2):166-71. [pmid: 8308509].
90 Killen JD, Fortmann SP, Davis L, Varady A. Nicotine patch and self-help video for cigarette smoking cessation. J Consult Clin Psychol. 1997;65(4):663-72. [pmid: 9256568].
91 Killen JD, Fortmann SP, Kraemer HC, Varady AN, Davis L, Newman B. Interactive effects of depression symptoms, nicotine dependence, and weight change on late smoking relapse. J Consult Clin Psychol. 1996;64(5):1060-7. [pmid: 8916636].
92 Shiffman S, Paty JA, Gnys M, Kassel JA, Hickcox M. First lapses to smoking: within-subjects analysis of real-time reports. J Consult Clin Psychol. 1996;64(2):366-79. [pmid: 8871421].
93 Fiore MC. The new vital sign. Assessing and documenting smoking status. JAMA. 1991;266(22):3183-3184. [pmid: 1823545].
94 Pallonen UE, Velicer WF, Prochaska JO, Rossi JS, Bellis JM, Tsoh JY, et al. Computer-based smoking cessation interventions in adolescents: description, feasibility, and six-month follow-up findings. Substance Use & Misuse. 1998;33(4):935-65. [pmid: 9548631].
95 Strecher VJ, Kreuter M, Den Boer DJ, Kobrin S, Hospers HJ, Skinner CS. The effects of computer-tailored smoking cessation messages in family practice settings. J Fam Pract. 1994;39(3):262-70. [pmid: 8077905].
96 Davis AL, Faust R, Ordentlich M. Self-help smoking cessation and maintenance programs: a comparative study with 12-month follow-up by the American Lung Association. Am J Public Health. 1984;74(11):1212-7. [pmid: 6437257].
97 Lando HA, Rolnick S, Klevan D, Roski J, Cherney L, Lauger G. Telephone support as an adjunct to transdermal nicotine in smoking cessation. Am J Public Health. 1997;87(10):1670-4. [pmid: 9357351].
98 Ossip-Klein DJ, Giovino GA, Megahed N, Black PM, Emont SL, Stiggins J, et al. Effects of a smoker's hotline: results of a 10-county self-help trial. J Consult Clin Psychol. 1991;59(2):325-32. [pmid: 2030195].
99 Platt S, Tannahill A, Watson J, Fraser E. Effectiveness of antismoking telephone helpline: follow up survey. BMJ. 1997;314(7091):1371-5. [pmid: 9161308].
100 Kenford SL, Fiore MC, Jorenby DE, Smith SS, Wetter D, Baker TB. Predicting smoking cessation. Who will quit with and without the nicotine patch. JAMA. 1994;271(8):589-94. [pmid: 8301790].
101 Marcus B, Albrecht A, King T, Parisi Aea. Efficacy of exercise as an aid for smoking cessation in women. Arch Intern Med. 1999;159:1229-34. [pmid: 10371231].
102 Hall SM, Munoz RF, Reus VI. Cognitive-behavioral intervention increases abstinence rates for depressive-history smokers. J Consult Clin Psychol. 1994;62(1):141-6. [pmid: 8034816].
103 Hall SM, Munoz RF, Reus VI, Sees KL, Duncan C, Humfleet GL, et al. Mood management and nicotine gum in smoking treatment: a therapeutic contact and placebo-controlled study. J Consult Clin Psychol. 1996;64(5):1003-9. [pmid: 8916629].
104 Abbot N, Stead L, White ABJ, Ernst E. Hypnotherapy for smoking cessation (Cochrane Review). The Cochrane Library 1999; (1).
105 Dijkstra A, de Vries H, Roijackers J, van Breukelen G. Tailoring information to enhance quitting in smokers with low motivation to quit: three basic efficacy questions. Health Psychol. 1998;17(6):513-9. [pmid: 9848801].
106 Strecher V. Computer-tailored smoking cessation materials: a review and discussion. Patient Education and Counseling. 1999;36:107-17. [pmid: 10223016].
107 Velicer W, Prochaska JO. An expert system intervention for smoking cessation. Patient Education and Counseling. 1999;36:119-29. [pmid: 10223017].
108 Cinciripini PM, Lapitsky L, Seay S, Wallfisch A, Kitchens K, Van V. The effects of smoking schedules on cessation outcome: can we improve on common methods of gradual and abrupt nicotine withdrawal?. J Consult Clin Psychol. 1995;63(3):388-99. [pmid: 7608351].
109 Herrera N, Franco R, Herrera L, Partidas A, Rolando R, Fagerstrom KO. Nicotine gum, 2 and 4 mg, for nicotine dependence. A double-blind placebo-controlled trial within a behavior modification support program. Chest. 1995;108(2):447-51. [pmid: 7634882].
110 Kornitzer M, Kittel F, Dramaix M, Bourdoux P. A double blind study of 2 mg versus 4 mg nicotine-gum in an industrial setting. J Psychosom Res. 1987;31(2):171-6. [pmid: 3295212].
111 Fagerstrom KO. Combined use of nicotine replacement products. Health Values. 1994;18(3):15-20.
112 Stapleton J. Commentary: Progress on nicotine replacement therapy for smokers [comment]. BMJ. 1999;318(7179). [pmid: 10075460].
113 Kornitzer M, Bousten M, Thijs J, Gustavsson G. Efficiency and safety of combined use of nicotine patches and nicotine gum in smoking cessation: A placebo controlled double-blind trial. Eur Respri J. 1993;6(17 Suppl).
114 Puska P, Korhonen H, Vartiainen E, Urjanheimo EL, Gustavsson G, Westin A. Combined use of nicotine patch and gum compared with gum alone in smoking cessation: a clinical trial in North Karelia. Tob Control. 1995;4:231-5.
115 Blondal T, Gudmundsson LJ, Olafsdottir I, Gustavsson G, Westin A. Nicotine nasal spray with nicotine patch for smoking cessation: Randomized trial with six year follow up. BMJ. 1999;318:285-8. [pmid: 9924052]. [pmcid: 27708].
116 Fagerstrom KO. Effectiveness of nicotine patch and nicotine gum as individual versus combined treatments for tobacco withdrawal symptoms. Psychopharmacology. 1993;111:271-7. [pmid: 7870963].
117 Hughes JR, Cummings KM, Hyland A. Ability of smokers to reduce their smoking and its association with future smoking cessation. Addiction. 1999;94(1):109-14. [pmid: 10665102].
118 Jorenby DE, Leischow S, Nides M, Rennard S, Johnston JA, Hughes AR, et al. A controlled trial of sustained-release bupropion, a nicotine patch, or both for smoking cessation. N Engl J Med. 1999;340(9):685-91. [pmid: 10053177].
119 Jorenby DE, Smith SS, Fiore MC, Hurt RD, Offord KP, Croghan IT, et al. Varying nicotine patch dose and type of smoking cessation counseling. JAMA. 1995;274(17):1347-52. [pmid: 7563558].
120 Tonnesen P, Paoletti P, Gustavsson G, Russell MA, Saracci R, Gulsvik A, et al. Higher dosage nicotine patches increase one-year smoking cessation rates: results from the European CEASE trial. Eur Respir J. 1999;13:238-246. [pmid: 10065662].
121 Anda RF, Williamson DF, Escobedo LG, Mast EE, Giovino GA, Remington PL. Depression and the dynamics of smoking. A national perspective. JAMA. 1990;264(12):1541-5. [pmid: 2395193].
122 Breslau N, Kilbey MM, Andreski P. Nicotine withdrawal symptoms and psychiatric disorders: findings from an epidemiologic study of young adults. Am J Psychiatry. 1992;149(4):464-9. [pmid: 1554030].
123 Glassman AH, Helzer JE, Covey LS, Cottler LB, Stetner F, Tipp JE, et al. Smoking, smoking cessation, and major depression. JAMA. 1990;264(12):1546-9. [pmid: 2395194].
124 Farebrother MJB, Pearce SJ, Turner P, Appleton DR. Propranolol and giving up smoking. Br J Dis Chest. 1980;74(1):95-96. [pmid: 6986897].
125 Wei H, Young D. Effect of clonidine on cigarette cessation and in the alleviation of withdrawal symptoms. Br J Addict. 1988;83:1221-6. [pmid: 3056540].
126 Cinciripini PM, Lapitsky L, Seay S, Wallfisch A, Meyer WJ 3rd, van Vunakis H. A placebo-controlled evaluation of the effects of buspirone on smoking cessation: differences between high- and low-anxiety smokers [published erratum appears in J Clin Psychopharmacol 1995 Dec;15(6):408]. J Clin Psychopharmacol. 1995;15(3):182-91. [pmid: 7635995].
127 Schneider NG, Olmstead RE, Steinberg C, Sloan K, Daims RM, Brown HV. Efficacy of buspirone in smoking cessation: a placebo-controlled trial. Clin Pharmacol Ther. 1996;60(5):568-75. [pmid: 8941030].
128 Hymowitz N, Eckholdt H. Effects of a 2. 5-mg silver acetate lozenge on initial and long-term smoking cessation. Prev Med. 1996;25(5):537-46. [pmid: 8888321].
129 Jensen EJ, Schmidt E, Pedersen B, Dahl R. The effect of nicotine, silver acetate, and placebo chewing gum on the cessation of smoking. The influence of smoking type and nicotine dependence. Int J Addict. 1991;26(11):1231-3. [pmid: 1743819].
130 Rose JE, Behm FM, Westman EC. Nicotine-mecamylamine treatment for smoking cessation: the role of pre-cessation therapy. Exp Clin Psychopharmacol. 1998;6(3):331-43. [pmid: 9725117].
131 Rose JE, Behm FM, Westman EC, Levin ED, Stein RM, Ripka GV. Mecamylamine combined with nicotine skin patch facilitates smoking cessation beyond nicotine patch treatment alone. Clin Pharmacol Ther. 1994;56:86-99. [pmid: 8033499].
132 Fiore MC, Kenford SL, Jorenby DE, Wetter DW, Smith SS, Baker TB. Two studies of the clinical effectiveness of the nicotine patch with different counseling treatments. Chest. 1994;105(2):524-33. [pmid: 8306757].
133 Silagy C, Mant D, Fowler G, Lodge M. The effectiveness of nicotine replacement therapies in smoking cessation. Online J Curr Clin Trials 1994; Doc No 113: [7906 words; 110 paragraphs].
134 Nides MA, Rakos RF, Gonzales D, Murray RP, Tashkin DP, Bjornson B, et al. Predictors of initial smoking cessation and relapse through the first 2 years of the Lung Health Study. J Consult Clin Psychol. 1995;63(1):60-9. [pmid: 7896992].
135 Hajek P, Jackson P, Belcher M. Long-term use of nicotine chewing gum. Occurrence, determinants, and effect on weight gain. JAMA. 1988;260(11):1593-6. [pmid: 3411739].
136 Hughes JR, Wadland WC, Fenwick JW, Lewis J, Bickel WK. Effect of cost on the self-administration and efficacy of nicotine gum: A preliminary study. Prev Med. 1991;20:486-96. [pmid: 1908080].
137 Henningfield JE. Nicotine medications for smoking cessation. [Review] [101 refs]. N Engl J Med. 1995;333(18):1196-203. [pmid: 7565976].
138 Hall SM, Reus VI, Munoz RF, Sees KL, Humfleet G, Hartz DT, et al. Nortriptyline and cognitive-behavioral therapy in the treatment of cigarette smoking. Arch Gen Psychiatry. 1998;55(8):683-90. [pmid: 9707377].
139 Hayford K, Patten C, Rummans D, Offord KP, et al. Efficacy of bupropion for smoking cessation in smokers with a former history of major depression or alcoholism. Br J Psychiatry. 1999;174:173-8. [pmid: 10211174].
140 Bjornson W, Rand C, Connett JE, Lindgren P, Nides M, Pope F, et al. Gender differences in smoking cessation after 3 years in the Lung Health Study. Am J Public Health. 1995;85(2):223-30. [pmid: 7856782].
141 Gritz ER, Thompson B, Emmons K, Ockene JK, McLerran DF, Nielsen IR. Gender differences among smokers and quitters in the Working Well Trial. Prev Med. 1998;27(4):553-61. [pmid: 9672949].
142 Hughes J, Goldstein MG. Recent advances in the pharmacotherapy of smoking. JAMA. 1999;281(1):72-6. [pmid: 9892454].
143 Hatsukami D, Severson H. Oral spit tobacco: addiction, prevention, and treatment. Nicotine Tob Res. 1999;1:21-44. [pmid: 11072386].
144 Benowitz NL, Gourlay SG. Cardiovascular toxicity of nicotine: implications for nicotine replacement therapy. J Am Coll Cardiol. 1997;29(7):1422-31. [pmid: 9180099].
145 Joseph AM, Norman SM, Ferry LH, Prochazka AV, Westman EC, Steele BG, et al. The safety of transdermal nicotine as an aid to smoking cessation in patients with cardiac disease. N Engl J Med. 1996;335(24):1792-8. [pmid: 8943160].
146 Mahmarian JJ, Moye LA, Nasser GA, et al. Nicotine patch therapy in smoking cessation reduces the extent of exercise-induced myocardial ischemia. J Am Coll Cardiol. 1997;30(1):125-30. [pmid: 9207632].
147 Working Group for the Study of Transdermal Nicotine in Patients with Coronary Artery Disease. Nicotine replacement therapy for patients with coronary artery disease. Arch Intern Med. 1994;154:989-95. [pmid: 8179456].
148 Leischow S, Muramoto ML, Cook G, Merikle E, Castellini S, Otte PS. OTC nicotine patches: effectiveness alone and with brief physician intervention. Am J Health Behav. 1999;23(1):61-9.
149 Pierce J, Giovino G, Hatziandreu E, Shopland D. National age and sex differences in quitting smoking. J Psychoactive Drugs. 1989;21(3):293-8. [pmid: 2809895].
150 Gritz E, Thompson B, Emmons K, Ockene J, McLerran DF, Nielsen IR. Gender differences among smokers and quitters in the Working Well Trial. Prev Med. 1998;27:553-61. [pmid: 9672949].
151 Perkins KA. Sex differences in nicotine versus nonnicotine reinforcement as determinants of tobacco smoking. Exp Clin Psychopharmacol. 1996;4(2):166-77.
152 Wetter D, Kenford S, Smith S, Fiore MC, Jorenby D, Baker T. Gender differences in smoking. J Consult Clin Psychol. 1999;67(4):555-62. [pmid: 10450626].
153 Gritz ER, Nielsen IR, Brooks LA. Smoking cessation and gender: the influence of physiological, psychological, and behavioral factors. [Review] [86 refs]. J Am Med Womens Assoc. 1996;51(1-2):35-42. [pmid: 8868547].
154 Ershoff DH, Mullen PD, Quinn VP. A randomized trial of a serialized self-help smoking cessation program for pregnant women in an HMO. Am J Public Health. 1989;79(2):182-7. [pmid: 2913837].
155 Walsh RA, Redman S, Brinsmead MW, Byrne JM, Melmeth A. A smoking cessation program at a public antenatal clinic. Am J Public Health. 1997;87(7):1201-4. [pmid: 9240113].
156 Windsor RA, Cutter G, Morris J, Reese Y, Manzella B, Bartlett EE, et al. The effectiveness of smoking cessation methods for smokers in public health maternity clinics: a randomized trial. Am J Public Health. 1985;75(12):1389-92. [pmid: 4061709].
157 Wisborg K, Henriksen TB, Obel C, Skajaa E. Smoking during pregnancy and hospitalization of the child. Pediatrics. 1999;104(4). [pmid: 10506271].
158 Mullen PD, Carbonari JP, Tabak ER, Glenday MC. Improving disclosure of smoking by pregnant women. Am J Obstet Gynecol. 1991;165(2):409-13. [pmid: 1872348].
159 Edwards N, Sims-Jones N. Smoking and smoking relapse during pregnancy and postpartum: results of a qualitative study. Birth. 1998;25(2):94-100. [pmid: 9668743].
160 Ko M, Schulken ED. Factors related to smoking cessation and relapse among pregnant smokers. Am J Health Behav. 1998;22(2):83-9.
161 McBride CM, Pirie PL. Postpartum smoking relapse. Addict Behav. 1990;15(2):165-8. [pmid: 2343790].
162 Severson HH, Andrews JA, Lichtenstein E, Wall M, Akers L. Reducing maternal smoking and relapse: long-term evaluation of a pediatric intervention. Prev Med. 1997;26(1):120-30. [pmid: 9010907].
163 Slotkin TA. Fetal nicotine or cocaine exposure: which one is worse?. J Pharmacol Exp Ther. 1998;285(3):931-45. [pmid: 9618392].
164 Dunner D, Zisook S, Billow A, Batey S, et al. A prospective safety surveillance study for bupropion sustained-release in the treatment of depression. J Clin Psychiatry. 1998;59(7):366-73. [pmid: 9714265].
165 Centers for Disease Control. Cigarette smoking among blacks and other minority populations. MMWR Morb Mortal Wkly Rep. 1987;36(25):405-7. [pmid: 3108653].
166 US Department of Health and Human Services. African Americans and tobacco. Surgeon General's Report on African Americans and Tobacco. 1998.
167 Coultas DB, Gong H, Jr., Grad R, Handler A, McCurdy SA, Player R, et al. Respiratory diseases in minorities of the United States. Am J Respir Crit Care Med. 1994;149(3 Pt 2):S93-S131. [pmid: 8118656].
168 Orleans CT, Schoenbach VJ, Salmon MA, Strecher VJ, Kalsbeek W, Quade D, et al. A survey of smoking and quitting patterns among Black Americans. Am J Public Health. 1989;79(2):176-81. [pmid: 2913836].
169 Stotts RC, Glynn TJ, Baquet CR. Smoking cessation among blacks. J Health Care Poor Underserved 1991; 2(2).
170 Brownson RC, Jackson-Thompson J, Wilkerson JC, Davis JR, Owens NW, Fisher EB, Jr. Demographic and socioeconomic differences in beliefs about the health effects of smoking. Am J Public Health. 1992;82(1):99-103. [pmid: 1536345].
171 Royce JM, Hymowitz N, Corbett K, Hartwell TD, and Orlandi MA, for the COMMIT Research Group. Smoking cessation factors among African Americans and whites. Am J Public Health. 1993;83(2):220-6. [pmid: 8427327].
172 Ahluwalia JS, McNagny SE, Clark WS. Smoking cessation among inner-city African Americans using the nicotine transdermal patch. J Gen Intern Med. 1998;13(1):1-8. [pmid: 9462488].
173 Lipkus IM, Lyna PR, Rimer BK. Using tailored interventions to enhance smoking cessation among African-Americans as a community health center. Nicotine Tob Res. 1999;1:77-85. [pmid: 11072391].
174 Royce JM, Ashford A, Resnicow K, Freeman HP, Caesar AA, Orlandi MA. Physician- and nurse-assisted smoking cessation in Harlem. J Natl Med Assoc. 1995;87(4):291-9. [pmid: 7752283].
175 Schorling J, Roach J, Baturka N, et al. A trial of church-based smoking cessation interventions for rural African Americans. Prev Med. 1997;26(1):92-101. [pmid: 9010903].
176 Orleans CT, Boyd NR, Bingler R, Sutton C, Fairclough D, Heller D, et al. A self-help intervention for African American smokers: tailoring cancer information service counseling for a special population. Prev Med. 1998;27(5 Pt 2):S61-S70. [pmid: 9808825].
177 Leischow SJ, Hill A, Cook G. The effects of transdermal nicotine for the treatment of Hispanic smokers. Am J Health Behav. 1996;20(5):304-11.
178 Munoz RF, Marin BV, Posner SF, Perez-Stable EJ. Mood management mail intervention increases abstinence rates for Spanish-speaking Latino smokers. Am J Community Psychol. 1997;25(3):325-43. [pmid: 9332966].
179 Johnson KM, Lando HA, Schmid LS, Solberg LI. The GAINS project: outcome of smoking cessation strategies in four urban Native American clinics. Giving American Indians No-smoking Strategies. Addict Behav. 1997;22(2):207-18. [pmid: 9113215].
180 Multiple Risk Factor Intervention Trial Research Group. Multiple Risk Factor Intervention Trial. Risk factor changes and mortality results. JAMA. 1982;248(12):1465-77. [pmid: 7050440].
181 Browman GP, Wong G, Hodson I, Sathya J, Russell R, McAlpine L, et al. Influence of cigarette smoking on the efficacy of radiation therapy in head and neck cancer. N Engl J Med. 1993;328(3):159-63. [pmid: 8417381].
182 Fujisawa T, Iizasa T, et al. Smoking before surgery predicts poor long-term survival in patients with stage I non-small-cell lung carcinomas. J Clin Oncol. 1999;17(7):2086-91. [pmid: 10561262].
183 Gritz E. Smoking and smoking cessation in cancer patients. British Journal of Addict. 1991;86:549-54.
184 Kawahara M, Ushijima S, et al. Second primary tumours in more than 2-year disease-free survivors of small-cell lung cancer in Japan: the role of smoking cessation. Br J Cancer. 1998;78(3):409-12. [pmid: 9703291].
185 Richardson G, Tucker M, Venzon D. Smoking cessation after successful treatment of small-cell lung cancer is associated with fewer smoking-related second primary cancers. Ann Intern Med. 1993;119(5):383-90. [pmid: 8393311].
186 Chang L, Buncke G, et al. Cigarette smoking, plastic surgery, and microsurgery. J Reconstr Microsurg. 1996;12(7):467-74. [pmid: 8905547].
187 Grossi SG, Genco RJ, Machtei EE, et al. Assessment of risk for periodontal disease. II. Risk indicators for alveolar bone loss. J Periodontol. 1995;66:23-9. [pmid: 7891246].
188 Jones RM. Smoking before surgery: the case for stopping [editorial]. BMJ (Clin Res Ed). 1985;290(6484):1763-4.
189 Hurt RD, Lauger GG, Offord KP, Bruce BK, Dale LC, McClain FL, et al. An integrated approach to the treatment of nicotine dependence in a medical center setting: Description of the initial experience. J Gen Intern Med. 1992;7:114-6. [pmid: 1312589].
190 Stevens VJ, Glasgow RE, Hollis JF, Lichtenstein E, Vogt TM. A smoking-cessation intervention for hospital patients. Med Care. 1993;31(1):65-72. [pmid: 8417271].
191 Brandon TH. Negative affect as motivation to smoke. Curr Psychol Res Rev. 1994;3(33):33-7.
192 Breslau N. Psychiatric comorbidity of smoking and nicotine dependence. Behav Genet. 1995;25:95-101. [pmid: 7733862].
193 Breslau N, Kilbey MM, Andreski P. DSM-III-R nicotine dependence in young adults: prevalence, correlates and associated psychiatric disorders. Addiction. 1994;89(6):743-54. [pmid: 8069175].
194 Glassman AH, Stetner F, Walsh BT, Raizman PS, Fleiss JL, Cooper TB, et al. Heavy smokers, smoking cessation, and clonidine: results of a double-blind, randomized trial. JAMA. 1988;259(19):2863-6. [pmid: 3367452].
195 Hall SM, Munoz RF, Reus VI, Sees KL. Nicotine, negative affect, and depression. J Consult Clin Psychol. 1993;61(5):761-7. [pmid: 7902368].
196 Budney AJ, Higgins ST, Hughes JR, Bickel WK. Nicotine and caffeine use in cocaine-dependent individuals. J Subst Abuse. 1993;5(2):117-30. [pmid: 8400835].
197 Clemmey P, Brooner R, Chutuape MA, Kidorf M, Stitzer M. Smoking habits and attitudes in a methadone maintenance treatment population. Drug Alcohol Depend. 1997;44(2-3):123-32. [pmid: 9088784].
198 DiFranza JR, Guerrera MP. Alcoholism and smoking. J Stud Alcohol. 1990;51(2):130-5. [pmid: 2308350].
199 Covey LS, Glassman AH, Stetner F. Cigarette smoking and major depression. [Review] [28 refs]. J Addict Dis. 1998;17(1):35-46. [pmid: 9549601].
200 Ginsberg JP, Klesges RC, Johnson KC, Eck LH, Meyers AW, Winders SA. The relationship between a history of depression and adherence to a multicomponent smoking-cessation program. Addict Behav. 1997;22(6):783-7. [pmid: 9426796].
201 Glassman AH. Cigarette smoking: implications for psychiatric illness. Am J Psychiatry. 1993;150(4):546-53. [pmid: 8465868].
202 Glassman AH, Covey LS, Dalack GW, Stetner F, Rivelli SK, Fleiss J, et al. Smoking cessation, clonidine, and vulnerability to nicotine among dependent smokers. Clin Pharmacol Ther. 1993;54(6):670-9. [pmid: 8275622].
203 Breckenridge JS. Smoking by outpatients. Hosp Community Psychiatry. 1990;41(4):454-5. [pmid: 2332234].
204 Burling TA, Marshall GD, Seidner AL. Smoking cessation for substance abuse inpatients. J Subst Abuse. 1991;3(3):269-76. [pmid: 1668228].
205 Hartman N, Jarvik ME, Wilkins JN. Reduction of cigarette smoking by use of a nicotine patch [letter]. Arch Gen Psychiatry. 1989;46(3). [pmid: 2645850].
206 Hartman N, Leong GB, Glynn SM, Wilkins JN, Jarvik ME. Transdermal nicotine and smoking behavior in psychiatric patients. Am J Psychiatry. 1991;148(3):374-5. [pmid: 1992843].
207 Ziedonis DM, George TP. Schizophrenia and nicotine use: report of a pilot smoking cessation program and review of neurobiological and clinical issues. Schizophr Bull. 1997;23(2):247-54. [pmid: 9165635].
208 Zelman DC, Brandon TH, Jorenby DE, Baker TB. Measures of affect and nicotine dependence predict differential response to smoking cessation treatments. J Consult Clin Psychol. 1992;60(6):943-52. [pmid: 1460156].
209 Hurt RD, Eberman KM, Slade J, Karan L. Treating nicotine addiction in patients with other addictive disorders. In: Orleans CT, Slade J, editors. Nicotine addiction: principles and management. New York: Oxford, 1993:310-326.
210 Resnick MP. Treating nicotine addiction in patients with psychiatric comorbidity. In: Orleans CT, Slade J, editors. New York: Oxford University Press, 1993: 327-36.
211 Smith C, Pristach C, Cartagena M. Obligatory cessation of smoking by psychiatric inpatients. Psychiatr Serv. 1999;50(1):91-4. [pmid: 9890586].
212 Hughes JR. Pharmacotherapy for smoking cessation: unvalidated assumptions, anomalies, and suggestions for future research. [Review]. J Consult Clin Psychol. 1993;61(5):751-60. [pmid: 8245273].
213 Bobo JK, McIlvain HE, Lando HA, Walker RD, Leed-Kelly A. Effect of smoking cessation counseling on recovery from alcoholism: findings from a randomized community intervention trial. Addiction. 1998;93(6):877-87. [pmid: 9744123].
214 Ellingstad T, Sobell L, Sobell M, Cleland P. Alcohol abusers who want to quit smoking: implications for clinical treatment. Drug Alcohol Depend. 1999;54(3):259-65. [pmid: 10372799].
215 UMI News and Information Services. Drug use by America's young people. MTFP 1998.
216 Green DE. Teenage smoking: immediate and long-term patterns. Washington DC: National Institute of Education, 1979.
217 Johnston L, O'Malley PM, Bachman JG. National survey results on drug use from monitoring the future study. 1975-1994: vol. 1, secondary school students. Bethesda, Maryland: US Department of Health and Human Services, Public Health Service, National Institutes of Health, National Institute on Drug Abuse. NIH Publication No. 95-4025. 1995.
218 Pierce JP, Gilpin E. How long will today's new adolescent smoker be addicted to cigarettes?. Am J Public Health. 1996;86(2):253-6. [pmid: 8633747].
219 Pierce JP, Choi WS, Gilpin E, Farkas AJ, et al. Tobacco industry promotion of cigarettes and adolescent smoking. JAMA. 1998;279(7):511-5. [pmid: 9480360].
220 Centers for Disease Control and Prevention. Trends in smoking initiation among adolescents and young adults: United States, 1980-89. MMWR Morb Mortal Wkly Rep. 1995;44(28):521-5. [pmid: 7603427].
221 DiFranza, JR. Preventing teenage tobacco addiction. J Fam Pract. 1992;34(6):753-6. [pmid: 1593250].
222 Lynch B, Bonnie RJ, editors. Institute of Medicine Committee on Preventing Nicotine Addiction in Children and Youths. Growing up tobacco free: preventing nicotine addiction in children and youths. Washington (DC): Natl Acad Press, 1994.
223 Centers for Disease Control and Prevention. Fastats. Fastats: CDC Publication 1999; www.cdc.gov/nchswww/fastats/smoking.htm.
224 Moss AJ, Allen KF, Giovino GA, Mills SL. Recent trends in adolescent smoking, smoking-uptake correlates, and expectations about the future. Adv Data. 1992;(221):1-28. [pmid: 10125952].
225 Sussman S, Lichtman K, Ritt A, Pallonen UE. Effects of thirty-four adolescent tobacco use cessation and prevention trials on regular users of tobacco products. Substance Use & Misuse. 1999;34(11):1469-503. [pmid: 10468104].
226 Wahlgren DR, Hovell MF, Slymen DJ, Conway TL, Hofstetter CR, Jones JA. Predictors of tobacco use initiation in adolescents: a two-year prospective study and theoretical discussion. Tob Control. 1997;6(2):95-103. [pmid: 9291217].
227 Wall MA, Severson HH, Andrews JA, Lichtenstein E, Zoref L. Pediatric office-based smoking intervention: impact on maternal smoking and relapse. Pediatrics. 1995;96(4 Pt 1):622-8. [pmid: 7567321].
228 Smith TA, House RFJ, Croghan IT, Gauvin TR, Colligan RC, Offord KP, et al. Nicotine patch therapy in adolescent smokers. Pediatrics. 1996;98(4 (Pt 1)):659-67. [pmid: 8885942].
229 Rimer BK, Orleans CT, Fleisher L, Cristinzio S, Resch N, Telepchak J, et al. Does tailoring matter? The impact of a tailored guide on ratings and short-term smoking-related outcomes for older smokers. Health Educ Res. 1994;9(1):69-84. [pmid: 10146734].
230 Cohen D, Fowlie S. Changing lifelong habits of elderly people. BMJ. 1992;304:1055-6. [pmid: 1472187].
231 Hermanson B, Omenn GS, Kronmal RA, Gersh BJ. Beneficial six-year outcome of smoking cessation in older men and women with coronary artery disease. Results from the CASS registry. N Engl J Med. 1988;319(21):1365-9. [pmid: 3185646].
232 Rogers RL, Meyer JS, Judd BW, et al. Abstention from cigarette smoking improves cerebral perfusion among elderly chronic smokers. JAMA. 1985;253(20):2970-4. [pmid: 3873549].
233 Boyd NR. Smoking cessation: a four-step plan to help older patients quit. [Review] [21 refs]. Geriatrics. 1996;51(11):52-7. [pmid: 8918483].
234 Burton LC, Paglia MJ, German PS, Shapiro S, Damiano AM. The Medicare Preventive Services Research Team. The effect among older persons of a general preventive visit on three health behaviors: smoking, excessive alcohol drinking, and sedentary lifestyle. Prev Med. 1995;24(5):492-7. [pmid: 8524724].
235 Morgan GD, Noll EL, Orleans CT, Rimer BK, Amfoh K, Bonney G. Reaching midlife and older smokers: tailored interventions for routine medical care. Prev Med. 1996;25(3):346-54. [pmid: 8781013].
236 Vetter NJ, Ford D. Smoking prevention among people aged 60 and over: a randomized controlled trial. Age Ageing. 1990;19(3):164-8. [pmid: 2194387].
237 Kviz FJ, Clark MA, Crittenden KS, Freels S, Warnecke RB. Age and readiness to quit smoking. Prev Med. 1994;23(2):211-22. [pmid: 8047528].
238 Ossip-Klein DJ, Carosella AM, Krusch DA. Self-help interventions for older smokers. Tob Control. 1997;6(3):188-93. [pmid: 9396102].
239 Orleans CT, Resch N, Noll E, Keintz MK, Rimer BK, Brown TV, et al. Use of transdermal nicotine in a state-level prescription plan for the elderly. A first look at 'real-world' patch users. JAMA. 1994;271(8):601-7. [pmid: 8301792].
240 Froom P, Melamed S, Benbassat J. Smoking cessation and weight gain. [Review] [61 refs]. J Fam Pract. 1998;46(6):460-4. [pmid: 9638109].
241 Klesges RC, Winders SE, Meyers AW, Eck LH, Ward KD, Hultquist CM, et al. How much weight gain occurs following smoking cessation? A comparison of weight gain using both continuous and point prevalence abstinence. J Consult Clin Psychol. 1997;65(2):286-91. [pmid: 9086692].
242 Williamson DF, Madans J, Anda RF, Kleinman JC, Giovino GA, Byers T. Smoking cessation and severity of weight gain in a national cohort. N Engl J Med. 1991;324(11):739-45. [pmid: 1997840].
243 Burnette MM, Meilahn E, Wing RR, Kuller LH. Smoking cessation, weight gain, and changes in cardiovascular risk factors during menopause: the Healthy Women Study. Am J Public Health. 1998;88(1):93-6. [pmid: 9584041].
244 Becona E, Vazquez FL. Smoking cessation and weight gain in smokers participating in a behavioral treatment at 3-year follow-up. Psychol Rep. 1998;82(3 Pt 1):999-1005. [pmid: 9676511].
245 Caan B, Coates A, Schaefer C, Finkler L, Sternfeld B, Corbett K. Women gain weight 1 year after smoking cessation while dietary intake temporarily increases. J Am Diet Assoc. 1996;96(11):1150-5. [pmid: 8906140].
246 Emont SC, Cummings KM. Weight gain following smoking cessation: a possible role for nicotine replacement in weight management. Addict Behav. 1987;12:151-5. [pmid: 3630801].
247 Frederick SL, Hall SM, Humfleet GL, Munoz RF. Sex differences in the relation of mood to weight gain after quitting smoking. Exp Clin Psychopharmacol. 1996;4(2):178-85.
248 Klesges RC, Ward KD, Ray JW, Cutter G, Jacobs DR Jr., Wagenknecht LE. The prospective relationships between smoking and weight in a young, biracial cohort: the Coronary Artery Risk Development in Young Adults Study. J Consult Clin Psychol. 1998;66(6):987-93. [pmid: 9874912].
249 Gritz ER, Crane LA. Use of diet pills and amphetamines to lose weight among smoking and nonsmoking high school seniors. Health Psychol. 1991;10(5):330-5. [pmid: 1935868].
250 Gritz ER, Klesges RC, Meyers AW. The smoking and body weight relationship: implications for intervention and postcessation weight control. Ann Behav Med. 1989;11(4):144-53.
251 Klesges RC, Klesges LM. Cigarette smoking as a dietary strategy in a university population. Int J Eat Disord. 1988;7:413-19.
252 Klesges RC, Meyers AW, Klesges LM, La Vasque ME. Smoking, body weight, and their effects on smoking behavior: A comprehensive review of the literature. Psychol Bull. 1989;106(2):204-30. [pmid: 2678202].
253 French S, Perry C, Leon G, Fulkerson J. Weight concerns, dieting behavior, and smoking initiation among adolescents: a prospective study. Am J Public Health. 1994;84(11):1818-20. [pmid: 7977924].
254 Gritz E, Crane LA. Use of diet pills and amphetamines to lose weight among smoking and nonsmoking high school seniors. Health Psychol. 1991;10(5):330-5. [pmid: 1935868].
255 Klesges RC, Elliott VE, Robinson LA. Chronic dieting and the belief that smoking controls body weight in a biracial, population-based adolescent sample. Tob Control. 1997;6(2):89-94. [pmid: 9291216].
256 Tomeo C, Field A, Berkey C, et al. Weight concerns, weight control behaviors, and smoking initiation. Pediatrics. 1999;104(4):918-24. [pmid: 10506235].
257 Camp D, Klesges RC, Relyea G. The relationship between body weight concerns and adolescent smoking. Health Psychol. 1993;12(1):24-32. [pmid: 8462495].
258 Hall SM, Tunstall CD, Vila KL, Duffy J. Weight gain prevention and smoking cessation: Cautionary findings. Am J Public Health. 1992;82(6):799-803. [pmid: 1585959].
259 Perkins KA. Issues in the prevention of weight gain after smoking cessation. Ann Behav Med. 1994;16:46-52.
260 Pirie PL, McBride CM, Hellerstedt W, Jeffery RW, Hatsukami D, Allen S, et al. Smoking cessation in women concerned about weight. Am J Public Health. 1992;82(9):1238-43. [pmid: 1503165].
261 Kawachi I, Troisi RJ, Rotnitzky AG, Coakley EH. Can physical activity minimize weight gain in women after smoking cessation?. Am J Public Health. 1996;86(7):999-1004. [pmid: 8669525].
262 Dale LC, Schroeder DR, Wolter TD, Croghan IT, Hurt RD, Offord KP. Weight change after smoking cessation using variable doses of transdermal nicotine replacement. J Gen Intern Med. 1998;13(1):9-15. [pmid: 9462489].
263 Doherty K, Militello FS, Kinnunen T, Garvey AJ. Nicotine gum dose and weight gain after smoking cessation. J Consult Clin Psychol. 1996;64(4):799-807. [pmid: 8803371].
264 Gross J, Stitzer ML, Maldonado J. Nicotine replacement: effects on postcessation weight gain. J Consult Clin Psychol. 1989;57(1):87-92. [pmid: 2925978].
265 Nides M, Rand C, Dolce J, Murray R, O'Hara P, Voelker H et al. Weight gain as a function of smoking cessation and 2-mg nicotine gum use among middle-aged smokers with mild lung impairment in the first 2 years of the Lung Health Study. Health Psychol. 1994;13(4):354-61. [pmid: 7957014].
266 Hurt RD, Sachs DP, Glover ED, Offord KP, Johnston JA, Dale LC, et al. A comparison of sustained-release bupropion and placebo for smoking cessation. N Engl J Med. 1997;337(17):1195-202. [pmid: 9337378].
267 Jorenby DE. New developments in approaches to smoking cessation. [Review] [33 refs]. Curr Opin Pulm Med. 1998;4(2):103-6. [pmid: 9612673].
268 Gray CL, Cinciripini PM, Cinciripini LG. The relationship of gender, diet patterns, and body type to weight change following smoking reduction: a multivariate approach. J Subst Abuse. 1995;7(4):405-23. [pmid: 8838624].
269 Hatsukami D, LaBounty L, Hughes J, Laine D. Effects of tobacco abstinence on food intake among cigarette smokers. Health Psychol. 1993;12(6):499-502. [pmid: 8293734].
270 Hofstetter A, Schutz Y, Jequier E, Wahren J. Increased 24-hour energy expenditure in cigarette smokers. N Engl J Med. 1986;314(2):79-82. [pmid: 3941694].
271 Klesges LM, Shumaker SA, editors. Proceedings of the national working conference on smoking and body weight. Health Psychol. 1992;11(suppl):1-22. [pmid: 1356758].
272 Moffatt RJ, Owens SG. Cessation from cigarette smoking: changes in body weight, body composition, resting metabolism, and energy consumption. Metabolism. 1991;40(5):465-70. [pmid: 2023532].
273 Schwid SR, Hirvonen MD, Keesey RE. Nicotine effects on body weight: a regulatory perspective. Am J Clin Nutr. 1992;55(4):878-884. [pmid: 1550071].
274 Noppa H, Bengtsson C. Obesity in relation to smoking: a population study of women in Goteborg, Sweden. Prev Med. 1980;9(4):534-43. [pmid: 7403022].
275 Stamford BA, Matter S, Fell RD, Papanek P. Effects of smoking cessation on weight gain, metabolic rate, caloric consumption, and blood lipids. Am J Clin Nutr. 1986;43(4):486-94. [pmid: 3962901].
276 Glover ED, Glover PN. Smokeless tobacco cessation and nicotine reduction therapy. In: Smoking and tobacco control: monograph 2 Smokeless tobacco or health: An international perspective U S Department of Health and Human Services, Public Health Service, National Institutes of Health, NIH Publication No 92-3461 1992; 291-296.
277 Marcus AC, Crane LA, Shopland DR, Lynn WR. Use of smokeless tobacco in the United States: recent estimates from the current population survey. NCI Monogr. 1989;(8):17-23. [pmid: 2785646].
278 Maxwell, J. The Maxwell consumer report: the smokeless tobacco industry in 1994. Richmond, VA, The Wheat First Butcher Singer. 1995.
279 Bolinder G, Alfredsson L, Englund A, et al. Smokeless tobacco use and increased cardiovascular mortality among Swedish construction workers. Am J Public Health. 1994;84:399-404. [pmid: 8129055]. [pmcid: 1614817].
280 Glover ED, Schroeder KL, Henningfield JE, Severson HH, Christen AG. An interpretative review of smokeless tobacco research in the United States: Part I. J Drug Educ. 1988;18(4):285-310. [pmid: 3065469].
281 Krall E, Garvey A, et al. Alveolar bone loss and tooth loss in male cigar and pipe smokers. J Am Dent Assoc. 1999;130:57-64. [pmid: 9919032].
282 Iribarren C, Tekawa I, Sidney S, Friedman G. Effect of cigar smoking on the risk of cardiovascular disease, chronic obstructive pulmonary disease, and cancer in men. N Engl J Med. 1999;340(23):1773-80. [pmid: 10362820].
283 National Cancer Institute. Cigars: Health effects and trends. Smoking and Tobacco Control Monograph No.9. Bethesda, Maryland, National Cancer Institute. NIH Publication No. 98-4302. 1998.
284 Severson HH, Andrews JA, Lichtenstein E, Gordon JS, Barckley MF. Using the hygiene visit to deliver a tobacco cessation program: results of a randomized clinical trial. J Am Dent Assoc. 1998;129(7):993-9. [pmid: 9685764].
285 Stevens VJ, Severson H, Lichtenstein E, Little SJ, Leben J. Making the most of a teachable moment: a smokeless-tobacco cessation intervention in the dental office. Am J Public Health. 1995;85(2):231-5. [pmid: 7856783].
286 Lancaster, T., Silagy, C., Fowler, G., and Spiers, I. Training health professionals in smoking cessation. Cochrane Database of Systematic Reviews. Issue 4. 1999.
287 Ockene J, Zapka J. Changing provider behaviour: provider education and training. Tob Control. 1997;6(Suppl 1):S63-S67. [pmid: 9396127].
288 Cummings KM, Giovino G, Sciandra R, Koenigsberg M, Emont SL. Physician advice to quit smoking: who gets it and who doesn't. Am J Prev Med. 1987;3(2):69-75. [pmid: 3452345].
289 Ferry LH, Grissino L, Runfola P. Tobacco dependence curricula in US undergraduate medical education. JAMA. 1999;282(9):825-829. [pmid: 10478687].
290 Scott CS, Neighbor WE. Preventive care attitudes of medical students. Soc Sci Med. 1985;1(3):299-305. [pmid: 4035418].
291 Wechsler H, Levine S, Idelson RK, Rohman M, Taylor JO. The physician's role in health promotion- a survey of primary-care practitioners. Massachusetts Department of Public Health. 1983;308(2):97-100.
292 Jones C. Response to a smoking cessation workshop by family practice resident physicians. Tob Control. 1993;2:30-4.
293 Fiore MC, Epps RP, Manley MW. A missed opportunity. Teaching medical students to help their patients successfully quit smoking. JAMA. 1994;271(8):624-6. [pmid: 8301797].
294 Kottke TE, Solberg LI, Brekke ML, Conn SA, Maxwell P, Brekke MJ. A controlled trial to integrate smoking cessation advice into primary care practice: Doctors helping smokers, round III. J Fam Pract. 1992;34(6):701-8. [pmid: 1593243].
295 Nelson DE, Emont SL, Brackbill RM, Cameron LL, Peddicord J, Fiore MC. Cigarette smoking prevalence by occupation in the United States. A comparison between 1978 to 1980 and 1987 to 1990. J Occup Med. 1994;36(5):516-25. [pmid: 8027876].
296 Croghan IT, Offord KP, Evans RW, Schmidt S, Gomez-Dahl LC, Schroeder DR, et al. Cost-effectiveness of treating nicotine dependence: the Mayo Clinic experience. Mayo Clin Proc. 1997;72(10):917-24. [pmid: 9379693].
297 Meenan RT, Stevens VJ, Hornbrook MC, La Chance PA, Glasgow RE, Hollis, et al. Cost-effectiveness of a hospital-based smoking cessation intervention. Med Care. 1998;36(5):670-8. [pmid: 9596058].
298 Plans-Rubio P. Cost-effectiveness of cardiovascular prevention programs in Spain. Int J Technol Assess Health Care. 1998;14(2):320-9. [pmid: 9611906].
299 Lightwood JM, Phibbs C, Glantz SA. Short-term health and economic benefits of smoking cessation: low birth weight. Pediatrics. 1999;104(6):1312-20. [pmid: 10585982].
300 Marks JS, Koplan JP, Hogue CJ, Dalmat ME. A cost-benefit/cost-effectiveness analysis of smoking cessation for pregnant women. Am J Prev Med. 1990;6(5):282-9. [pmid: 2125228].
301 Warner KE. Cost effectiveness of smoking-cessation therapies. Interpretation of the evidence and implications for coverage. [Review] [41 refs]. PharmacoEconomics. 1997;11(6):538-49. [pmid: 10168094].
302 Cox JL, McKenna JP. Nicotine gum: does providing it free in a smoking cessation program alter success rates?. J Fam Pract. 1990;31(3):278-80. [pmid: 2391458].
303 Johnson RE, Hollis JF, Stevens VJ, Woodson GT. Patterns of nicotine gum use in a health maintenance organization. DICP. 1991;25(7-8):730-5. [pmid: 1949928].
304 Henry RC, Ogle KS, Snellman LA. Preventive medicine: Physician practices, beliefs, and perceived barriers for implementation. Fam Med. 1987;19(2):110-3. [pmid: 3596091].
305 Logsdon DN, Lazaro CM, Meier RV. The feasibility of behavioral risk reduction in primary medical care. Am J Prev Med. 1989;5(5):249-56. [pmid: 2789846].
306 Centers for Disease Control and Prevention. Use of clinical preventive services by adults aged <65 years enrolled in health-maintenance organizations—United States, 1996. MMWR Morb Mortal Wkly Rep. 1998;47(29):613-9. [pmid: 9699811].
307 Davis RM. Healthcare report cards and tobacco measures. Tob Control. 1997;6(Suppl 1):570-7. [pmid: 9396129].
308 Hughes JR. Applying harm reduction to smoking. Tob Control. 1995;4(Suppl 2):S33-S38.
309 Rosengren A, Wilhelmsen L, Wedel H. Coronary heart-disease, cancer, and mortality in male middle-aged light smokers. J Intern Med. 1992;231(4):357-62. [pmid: 1588259].
310 US Department of Health and Human Services. The FTC cigarette test method for determining tar, nicotine, and carbon monoxide yields of US cigarettes: report of the NCI expert committee. Bethesda, MD, National Institutes of Health Publication. Publication No. 96-4028. 1996.
311 Henningfield J, Benowitz N, Slade J, Houston T, Davis RM, Deitchman S. Reducing the addictiveness of cigarettes. Tob Control. 1998;7:281-93. [pmid: 9825424].