# Acknowledgments

This guideline would not have been possible without the collaborative efforts of many individuals and organizations. Each made significant contributions throughout the process of updating this guideline. While too numerous to list here, the Contributors section of this publication provides a listing of support staff, individual peer reviewers, and others. There are, however, some individuals and organizations that deserve special mention.

The panel wishes to acknowledge the support and guidance provided by the consortium partners in general and their dedicated hard working representatives in particular. Specifically, the panel gratefully acknowledges the extraordinarily supportive efforts and substantial contribution throughout the project of Ernestine W. Murray, RN, MAS, Panel Project Officer, Center for Practice and Technology Assessment; Agency for Healthcare Research and Quality (AHRQ). Additionally, we would like to recognize the outstanding contributions of other AHRQ staff: Douglas B. Kamerow, MD, MPH, Director, Center for Practice and Technology Assessment; Harriett V. Bennett, Public Affairs and Marketing Specialist, Office of Health Care Information; and Sandra Katz Cummings, Managing Editor, Office of Health Care Information. The panel particularly wishes to thank Glen D. Morgan, PhD, at the National Cancer Institute; Corinne Husten, MD, MPH, and Cathy Melvin, PhD, MPH, Office on Smoking and Health at the Centers for Disease Control and Prevention; Glen Bennett, MPH, at the National Heart, Lung, and Blood Institute; Stephen J. Heishman, PhD, at the National Institute on Drug Abuse; C. Tracy Orleans, PhD, at the Robert Wood Johnson Foundation; and Douglas Jorenby, PhD, at the Center for Tobacco Research and Intervention, University of Wisconsin Medical School.

The Panel also wishes to thank Marc Manley, MD, MPH; John Mullahy, PhD; David Schriger, MD, MPH; and David Wetter, PhD, consultants on the project, for their insight and intellectual contributions.

Finally, the panel extends its gratitude and appreciation to the staff members at the University of Wisconsin Medical School Center for Tobacco Research and Intervention for their tireless efforts in bringing this project to completion. In particular, the panel acknowledges and thanks Bridget Whisler, Project Manager; and Megan Piper, MA, and Sam Welsch, Senior Research Associates.