# Guideline Panel

- Michael C. Fiore, MD, MPH (Panel Chair)
- William C. Bailey, MD
- Stuart J. Cohen, EdD
- Sally Faith Dorfman, MD, MSHSA
- Michael G. Goldstein, MD
- Ellen R. Gritz, PhD
- Richard B. Heyman, MD
- Carlos Roberto Jaén, MD, PhD
- Thomas E. Kottke, MD, MSPH
- Harry A. Lando, PhD
- Robert E. Mecklenburg, DDS, MPH
- Patricia Dolan Mullen, DrPH
- Louise M. Nett, RN, RRT
- Lawrence Robinson, MD, MPH
- Maxine L. Stitzer, PhD
- Anthony C. Tommasello, MS
- Louise Villejo, MPH, CHES
- Mary Ellen Wewers, PhD, RN

Guideline Staff

- Timothy Baker, Ph.D.
- Brion J. Fox, J.D.
- Victor Hasselblad, Ph.D.