# Special Topics

## Background

Many additional factors that influence the efficacy of tobacco dependence interventions were considered by the panel. These include weight gain after cessation, the treatment of tobacco users other than cigarette smokers, and institutional barriers that may interfere with tobacco users receiving treatment. This chapter provides the panel's recommendations and supporting evidence on these disparate topics.

## Weight Gain After Smoking Cessation

Recommendation: The clinician should acknowledge that quitting smoking is often followed by weight gain. Additionally, the clinician should: (1) note that the health risks of weight gain are small when compared to the risks of continued smoking; (2) recommend physical activities and a healthy diet to control weight; and (3) recommend that patients concentrate primarily on smoking cessation, not weight control, until ex-smokers are confident that they will not return to smoking. (Strength of Evidence = C)

Recommendation: For smokers who are greatly concerned about weight gain, it may be most appropriate to prescribe or recommend bupropion SR or NRT, in particular nicotine gum, which have been shown to delay weight gain after quitting. (Strength of Evidence = B)

The majority of smokers who quit smoking gain weight. Most will gain fewer than 10 pounds, but there is a broad range of weight gain, with as many as 10 percent of quitters gaining as much as 30 pounds.^240,^ ^241,^ ^242^ However, weight gain that follows smoking cessation is a negligible health threat compared with the risks of continued smoking.^242,^ ^243^

Women tend to gain slightly more weight than men do.^242^ For both sexes, African Americans, people under age 55, and heavy smokers (those smoking more than 25 cigarettes/day) are at elevated risk for major weight gain.^240,^ ^242,^ ^244,^ ^245,^ ^246,^ ^247,^ ^248^

For some smokers, especially women, concerns about weight or fears about weight gain are motivators to start smoking or continue smoking.^249,^ ^250,^ ^251,^ ^252^ Adolescents, even as young as junior high age, who are concerned about their weight initiate smoking more often than do other adolescents.^253,^ ^254,^ ^255,^ ^256^

Concern about weight varies substantially by ethnicity. For example, adolescent African American females are much less likely to report that they smoke to control weight than are European Americans.^257^ This is an important area for further study, as little tobacco research focuses on women of minority ethnicities.^257^

Some evidence suggests that attempts to prevent weight gain (e.g., strict dieting) may undermine the attempt to quit smoking.^258,^ ^259,^ ^260^ Other evidence suggests that weight gain is reduced if smoking cessation is accompanied by a moderate increase in physical activity.^261^ One recent study showed that an exercise program, occurring in three 45-minute sessions per week, increases long-term smoking abstinence in women and delays weight gain when it is combined with a cognitive-behavioral smoking cessation program.^101^

Nicotine replacement-in particular, nicotine gum-appears to be effective in delaying postcessation weight gain. Moreover, there appears to be a dose-response relation between gum use and weight suppression (i.e., the greater the gum use, the less weight gain occurs). However, once nicotine gum use ceases, the quitting smoker gains an amount of weight that is about the same as if she or he had never used gum.^246,^ ^262,^ ^263,^ ^264,^ ^265^

Bupropion SR also appears to be effective in delaying post-cessation weight gain.^118,^ ^266,^ ^267^ However, once bupropion SR therapy is stopped, the quitting smoker, on average, gains an amount of weight that is about the same as if she or he had not used bupropion SR.^118,^ ^266^

Postcessation weight gain appears to be caused both by increased intake (e.g., eating and alcohol consumption) and by metabolic adjustments. The involvement of metabolic mechanisms suggests that even if smokers do not increase their caloric intake upon quitting, they will, on average, gain some weight.^268,^ ^269,^ ^270,^ ^271,^ ^272,^ ^273^ Once an individual relapses and begins smoking at precessation levels, he or she will usually lose some or all of the weight gained during the quit attempt.^272,^ ^274,^ ^275,^

The research evidence reviewed above illustrates why concerns about weight gain are barriers to smoking abstinence. Many smokers (especially women) are concerned about their weight and fear that quitting will produce weight gain. Many also believe that they can do little to prevent postcessation weight except to return to smoking. These beliefs are especially difficult to address clinically because they are congruent with research findings; that is, the beliefs have some basis in fact.

### Recommendations to Clinicians When Addressing Weight Gain

How should the clinician deal with concerns about weight gain? First, the clinician should neither deny the likelihood of weight gain nor minimize its significance to the patient. Rather, the clinician should inform the patient about the likelihood of weight gain and prepare the patient for its occurrence. However, the clinician should counter exaggerated fears about weight gain given the relatively moderate weight gain that typically occurs. Certain types of information may help prepare the patient for postcessation weight gain (see Table 46). Clinicians also should inform the patient that smoking presents a much greater health risk than the negligible health risk involved in the modest weight gain associated with smoking abstinence.

Table 46. Clinician statements to help a patient prepare for, and cope with, postcessation weight gain

Clinician statements
"The great majority of smokers gain weight once they quit smoking. However, even without special attempts at dieting or exercise, weight gain is usually limited to 10 lbs."
"There is evidence that smokers will gain weight once they quit smoking, even if they do not eat more. However, there are medications that will help you quit smoking and limit or delay weight gain. I can recommend one for you."
"The amount of weight you will likely gain from quitting will be a minor health risk compared with the risks of continued smoking."
"Try to put your concerns about weight on the back burner. You are most likely to be successful if you first try to quit smoking, and then later take steps to reduce your weight. Tackle one problem at a time! After you have quit smoking successfully, we can talk about how to reduce your weight."
"I know weight is important to you, and that you don't want to gain a lot of weight. However, temporarily -- just until you are confident that you have quit smoking for good -- let's focus on strategies to get you healthy rather than on weight. Think about eating plenty of fruit and vegetables, getting regular exercise, getting enough sleep, and not eating a lot of fats. Right now, this is probably the best thing you can do for both your weight and your effort to quit smoking."
"Although you may gain some weight after quitting smoking, compare the importance of this with the added years of healthy living you will gain, your better appearance (less wrinkled skin, whiter teeth, fresher breath), and good feelings about quitting."

Second, before and during the quit attempt the clinician should stress that quitting smoking is the patient's primary, immediate priority, and that the patient will be most successful in the long run if he or she does not take strong measures (e.g., strict dieting) to counteract weight gain during a quit attempt (see Table 46).

Third, during the quit attempt, the clinician should offer to help the patient address weight gain (either personally or via referral) once the patient has successfully quit smoking. Specifically, the clinician should recommend that intensive weight control strategies be avoided until the patient is no longer experiencing withdrawal symptoms and is confident that he or she will not return to smoking. The patient should, however, be encouraged to maintain or adopt a healthy lifestyle, including engaging in moderate exercise, eating plenty of fruits and vegetables, and limiting alcohol consumption.^101^

### Future Research

The following topics regarding weight gain during tobacco dependence treatment require additional research:

- The impact of weight gain concerns on women of minority ethnicities.
- The efficacy of weight control measures during quit attempts and their effect on tobacco abstinence and weight.
- The efficacy of pharmacotherapy to control weight gain during quit attempts.
- The efficacy of the use of exercise to control weight gain during a quit attempt.
- The impact of weight gain concerns on adolescent smoking.

## Noncigarette Tobacco Products

Recommendation: Smokeless/spit tobacco users should be identified, strongly urged to quit, and treated with the same counseling cessation interventions recommended for smokers. (Strength of Evidence = B)

Recommendation: Clinicians delivering dental health services should provide brief interventions to all smokeless/spit (chewing tobacco and snuff) tobacco users. (Strength of Evidence = A)

Recommendation: Users of cigars, pipes, and other noncigarette combustible forms of tobacco should be identified, strongly urged to quit, and offered the same counseling interventions recommended for smokers. (Strength of Evidence = C)

Like cigarette smoking, the use of smokeless or spit tobacco, such as chewing tobacco and snuff, produces addiction to nicotine and has serious health consequences. Consumption of such smokeless tobacco products has increased in recent years,^276,^ ^277,^ ^278^ especially among young males. Health risks from these products include abrasion of teeth, gingival recession, periodontal bone loss, leukoplakia, and oral cancer and cardiovascular disease.^279,^ ^280,^ ^281^ Thus, the use of smokeless tobacco is not a safe alternative to smoking.

Cigar smoking also poses serious health risks. Cigar smokers are at higher risk for coronary heart disease, COPD, lung and other cancers, with evidence of dose-response effects.^282,^ ^283,^ Cigar use is particularly concerning because cigar sales in the United States also have increased nearly 50 percent between 1993 and 1997.^282^ In 1997, an estimated 6 million U.S. teenagers ages 14-19 (37% of males, 16% of females) smoked at least one cigar within the past year. Clinicians also should be aware of and address the use of other noncigarette tobacco products, including pipes, cigarillos, loose tobacco, bidis, and betel quid.

A close review of the literature showed that there is evidence that dental health clinicians (e.g., dental hygienists) delivering brief advice to quit using smokeless/spit tobacco can increase abstinence rates.^284,^ ^285,^ Although somewhat limited, there is evidence that nonpharmacologic treatments used for smoking cessation also are effective in smokeless tobacco cessation. Therefore, clinicians should offer quitting advice and assistance to their patients who use tobacco regardless of the formulation of the tobacco product. Some information may be particularly relevant in the treatment of smokeless tobacco use. For instance, a large majority of moist snuff users have identifiable oral lesions, and this information may be useful in motivating a quit attempt.

Currently, there is insufficient evidence to suggest that the use of tobacco dependence pharmacotherapies increases long-term abstinence among users of smokeless tobacco. Specifically, studies conducted with nicotine gum and the nicotine patch have shown that these two medications have not increased abstinence rates in this population.^143^

### Future Research

The following topics regarding non-cigarette tobacco products require additional research:

- The efficacy of advice and counseling treatments to promote abstinence among users of noncigarette tobacco products.
- The efficacy of pharmacotherapy treatments to promote abstinence among users of noncigarette tobacco products.
- The efficacy of combined pharmacotherapy and counseling and behavioral therapies with users of noncigarette tobacco products.

## Clinician Training

Recommendation: All clinicians and clinicians-in-training should be trained in effective strategies to assist tobacco users willing to make a quit attempt and to motivate those unwilling to quit at this time. (Strength of Evidence = B)

The above recommendation is based on panel review of the published literature rather than a formal meta-analysis. Relevant studies focused primarily on physician training. Many of these studies examined the impact of training as it co-occurred with other systems changes such as reminder systems or staff education.^286,^ ^287^ Training appears to be more effective when coupled with these systems changes.

Clinicians must be trained in effective tobacco use treatments if guideline recommendations are to be implemented. The importance of training is clear in that clinicians report lack of relevant knowledge as a significant barrier to intervening with their patients who use tobacco.^288,^ ^289,^ ^290,^ ^291^

Training should be directed at both clinicians-in-training as well as practicing clinicians. Training should be reinforced throughout the clinicians' education and practice.^292^ For clinicians-in-training, most disciplines neither provide training, nor require competency, in tobacco use interventions. For example, an NCI expert panel found that medical schools do not consistently train students in effective smoking cessation interventions.^293^ That panel recommended that a specific curriculum devoted to tobacco dependence treatment be included as part of each medical student's education. This curriculum may be taught as part of a preventive medicine or substance abuse course or as a class by itself. Similar recommendations would be relevant to virtually all other clinical disciplines. More recently, a survey of U.S. medical schools found that most medical schools (69%) did not require clinical training in tobacco dependence treatment.^289^ Training in tobacco use interventions should not only transmit essential treatment skills but also inculcate the belief that cessation treatment is a standard of good practice.^294^

Practicing clinicians also would benefit from continuing education that addresses tobacco dependence treatment. This guideline recommends that clinicians be reimbursed for treating tobacco dependence and that their intervention activities be tracked. Either of these policies should foster increased interest in establishing expertise in treating tobacco use among practicing clinicians.

Several factors would promote the training of clinicians in tobacco intervention activities:^293^

- Inclusion of education and training in tobacco dependence treatments in the required curricula of all clinical disciplines.
- Inclusion of questions on effective tobacco dependence treatment in licensing and certification exams for all clinical disciplines.
- Adoption by specialty societies of a uniform standard of competence in tobacco dependence treatment for all members.

Finally, clinicians who currently use any tobacco product should participate in treatment programs to stop their own tobacco use permanently. Clinicians have an important role as models for their patients. Therefore, it is heartening that many types of clinicians have dramatically decreased their tobacco use over the past 20 years. In a report on tobacco-use prevalence by occupation, the rate of smoking was noted to be 5.5 percent among physicians, 7.4 percent among dentists, 8.7 percent among physical therapists, and 22.0 percent among registered nurses.^295^ All of these prevalence rates are lower than tobacco-use rates in the general population.

### Future Research

The following topics regarding clinician training require additional research:

- The efficacy of training programs for other health disciplines such as nursing, psychology, dentistry (including hygienists), social work, and pharmacy.
- The effective elements in successful training programs (e.g., continuing medical education, interactive components).
- The efficacy of systems changes, such as reminder systems (and performance feedback), when implemented with training programs.

## Economic Aspects of Tobacco Dependence Treatments and Health Systems Interventions

Recommendation: The smoking cessation treatments shown to be efficacious in this guideline (both pharmacotherapy and counseling) are highly cost-effective relative to other reimbursed treatments (e.g., treatment of hyperlipidemia and mammography screening) and should be provided to all smokers. (Strength of Evidence = A)

Recommendation: Intensive smoking cessation interventions are especially efficacious and cost- effective, and smokers should have ready access to these services as well as to less intensive interventions. (Strength of Evidence = B)

Recommendation: Smoking cessation treatments (both pharmacotherapy and counseling) should be included as a paid or covered benefit by health benefits plans because doing so improves utilization and overall abstinence rates. (Strength of Evidence = B)

Recommendation: Sufficient resources should be allocated for clinician reimbursement and systems support to ensure the delivery of efficacious tobacco use treatments. (Strength of Evidence = C)

Recommendation: Provision of guideline-based interventions to treat tobacco use and addiction should be included in standard ratings and measures of overall health care quality (e.g., NCQA HEDIS, the Foundation for Accountability [FACCT]). (Strength of Evidence = C)

Smoking cessation treatments ranging from brief clinician advice to specialist-delivered intensive programs, including pharmacotherapy, are not only clinically effective, but also they are extremely cost-effective relative to other commonly used disease prevention interventions and medical treatments. Cost-effectiveness analyses have shown that smoking cessation treatment compares quite favorably with routinely reimbursed medical interventions such as the treatment of hypertension and hypercholesterolemia as well as preventive screening interventions such as periodic mammography or Papanicolaou smears.^28,^ ^71,^ ^75,^ ^76,^ ^77,^ ^296,^ ^297,^ ^298^ Treating tobacco dependence is particularly important economically in that it can prevent a variety of costly chronic diseases, including heart disease, cancer, and pulmonary disease. In fact, smoking cessation treatment has been referred to as the "gold standard" of preventive interventions.^78^

It is important to note that smoking cessation is also cost-effective in special populations such as hospitalized patients and pregnant women. For hospitalized patients, successful tobacco abstinence not only reduces general medical costs in the short-term, but also reduces the number of future hospitalizations.^16^ Smoking cessation interventions for pregnant women are especially cost-effective because they result in fewer low birth weight babies and perinatal deaths, fewer physical, cognitive, and behavioral problems during infancy and childhood, and also yield important health benefits for the mother.^299,^ ^300^

Although data suggest that, among clinical interventions, intensive interventions are more cost- effective than low-intensity interventions,^64^ widely disseminated public health interventions may have even greater cost-effectiveness.^301^

The failure of a health plan to cover tobacco dependence treatment as an insured benefit could reduce access to these services and reduce the number of people seeking these services. It has been found that when smoking cessation services are provided as a fully covered benefit by a health plan in contrast to a health plan that required a significant co-pay, the overall utilization of cessation treatment increases and smoking prevalence within the health plan will decrease.^66^ Moreover, the presence of prepaid or discounted prescription drug benefits increases patients' receipt of pharmacotherapy and smoking abstinence rates.^136,^ ^302,^ ^303^

Primary care clinicians frequently cite insufficient insurance reimbursement as a barrier to the provision of preventive services such as smoking cessation treatment.^304^ An 8-year insurance industry study found that reimbursing physicians for provision of preventive care resulted in reported increases in exercise, seat belt use, and weight loss, as well as decreased alcohol use and a trend toward decreased smoking.^305^

It may be in the best interests of insurance companies, managed care organizations, and governmental bodies within a specific geographic area to work collectively to ensure that tobacco dependence interventions are a covered benefit. This also would allow the financial benefits of these services to be realized by all the health plans within a community.

The provision of tobacco dependence treatment should be increased by: (1) attention to health plan "report cards" (e.g., NCQA, HEDIS),306,307 which support smoker identification and treatment; and (2) accreditation criteria used by JCAHO and other accrediting bodies that include the presence of effective tobacco assessment and intervention policies.

### Future Research

The following topics regarding cost-effectiveness and health systems require additional research:

- To what extent are the various tobacco dependence treatments cost-effective, both short and long term?
- What is the best way to remove systemic barriers that prevent clinicians from effectively delivering tobacco dependence treatments?
- What are the best systemic interventions to encourage provider and patient utilization of effective tobacco dependence treatments?
- Whether reimbursement for tobacco dependence treatment is recovered later in reduced health care costs.
- Evaluation of the relative costs and economic impacts of different formats of efficacious treatments (e.g., proactive telephone counseling, face-to-face contact, pharmacotherapy).

## Alternative Treatment Goals: Harm Reduction

There is insufficient evidence to support a recommendation regarding harm reduction interventions. In harm reduction strategies, tobacco users alter, rather than eliminate, their use of nicotine or tobacco to reduce or avoid its harmful consequences. Many harm reduction strategies have been proposed such as reduced use of tobacco (perhaps with the conjoint use of pharmacotherapy), use of less hazardous tobacco/nicotine products, or use of less addictive tobacco/nicotine products.^308^ It is difficult to evaluate the potential benefits of harm reduction strategies because of a lack of published data. For instance, it is unknown whether public health would ultimately be better served by smokers' attempting to reduce or shift their tobacco use (e.g., smoke fewer cigarettes) rather than by making repeated quit attempts. It must be borne in mind that all types of tobacco use (e.g., smokeless, pipe, cigar) carry significant health risks. Specifically, the use of smokeless/spit tobacco is not a safe alternative to smoking. Moreover, increased health risks have been documented even in "light" smokers (less than five cigarettes per day).^309^ Finally, evidence suggests that when smokers are forced to reduce their nicotine intake, they frequently engage in compensatory smoking (e.g., taking more puffs per cigarette, taking deeper puffs).^310^

In sum, it is not known whether harm reduction strategies would reduce tobacco exposure over the long-term, whether they would reduce negative health outcomes, whether their encouragement would yield greater benefits than an exclusive reliance on abstinence, and whether they might increase tobacco use prevalence by suggesting the availability of a "safe" tobacco strategy. As a result, prior to embracing any harm reduction strategy, extensive research will need to be performed on the feasibility, efficacy, and costs and benefits of these strategies. Some of the needed research includes:

- Are a significant number of smokers able to maintain smoking reduction behaviors (e.g., reduced quantity) for long periods of time? What techniques promote such reductions, and what are the characteristics of those who are able to reduce and those who are unable to do so?
- What degree of compensatory smoking occurs when smokers reduce the number of cigarettes smoked or smoke low tar cigarettes when:
  - - Aided by medications (e.g., bupropion SR or NRT)
  - - Unaided by medications
- What are the physiologic and health impacts of smoking reduction strategies (i.e., reduced smoking rate or use of low tar and/or low nicotine cigarettes) when:
  - - Aided by medications (e.g., bupropion SR or NRT)
  - - Unaided by medications
- Will a significant number of smokers use nontobacco medicines (e.g., bupropion SR and/or NRT) in lieu of smoking over the long term, and will this benefit health?
- What are the public health and clinical implications of recommending a harm reduction strategy in addition to abstinence strategies (e.g., a message such as "You should quit. If you can't quit, you should try to reduce.")?
- Would the forced reduction of the nicotine content of cigarettes by the tobacco companies constitute an effective societal intervention?^311^
- What medications are most effective in promoting reduced smoking (short and long term) without compensatory smoking?
- How effective are behavioral interventions in promoting reduced smoking (short and long term) without compensatory smoking?