# Evidence

## Background

The recommendations summarized in Chapters 2, 3, 4, and 5 are the result of a review and analysis of the extant tobacco cessation literature. The current chapter reports the results of this review and analysis, and describes the efficacy of various treatments, assessments, and strategies for their implementation. This chapter addresses such questions as: Does the professional discipline of the clinician make a difference in the efficacy of the intervention? Are different types of providers effective in delivering interventions? Are minimal interventions, such as clinician advice to quit smoking, effective or are more intensive interventions required? Does the duration of an intervention in number of treatment sessions or in total face-to-face contact time substantially influence efficacy? Are pharmacologic interventions effective, and if so, which ones? Which counseling strategies are particularly helpful? In short, which treatments or assessments are efficacious and how should they be used?

The panel examined the relation between outcomes and 10 major assessment or treatment characteristics or strategies. These 10 characteristic types, and the categories within each, are listed in Table 6. Type of outcome varied across the different characteristics being analyzed. In most analyses, long-term abstinence was the outcome measure, in others it was the rate of smoker identification. The analyses reported in this chapter almost exclusively addressed treatments for cigarette smoking, as opposed to the use of other forms of tobacco, as the small number of studies on the use of noncigarette tobacco products precluded their separate analysis. Finally, the panel attempted to analyze treatment and assessment strategies that constitute distinct approaches that exist in current clinical practice.

The panel chose categories within each characteristic according to three major criteria. First, some categories reflected generally accepted dimensions or taxonomies. An example of this is the categorical nature of the clinician types (physician, psychologist, nurse, and so on). Second, information on the category had to be available in the published literature. Many questions of theoretical interest had to be abandoned simply because the requisite information was not available. Third, the category had to occur with sufficient frequency to permit meaningful statistical analysis. For example, the cut-points of some continuous variables (e.g., total amount of contact time) were determined so there was a sufficient number of studies within each analytical category to permit meaningful analysis.

In ideal circumstances, the panel could evaluate each characteristic by consulting randomized controlled trials relevant to the specific categories in question. Unfortunately, with the exception of pharmacologic interventions, very few or no randomized controlled trials are specifically designed to address the effects of the various categories related to these treatment or assessment characteristics. Moreover, treatment characteristics are frequently confounded with one another. For example, comparisons among clinicians are almost always confounded with the type of counseling and behavioral therapy, format, and intensity of the interventions. Psychologists tend to deliver relatively intensive interventions, whereas physicians tend to deliver brief advice to individuals. Therefore, direct, unconfounded comparisons of categories within a particular characteristic were often impossible. These characteristics were nevertheless analyzed because of their clinical importance, and because it was possible to reduce confounding by careful selection of studies and by statistical control of some confounding factors.

Additional topics, which did not lend themselves to analysis due to a lack of published long-term abstinence data, yet were important and clinically relevant, were nevertheless considered by the panel through a review of the existing literature. The strength of evidence associated with these recommendations clearly indicate that they are not based on meta-analyzed randomized controlled trials.

The present chapter addresses the 10 treatment and assessment characteristics outlined in Table 6 and is divided into three sections: (A) screening and assessment, (B) treatment structure and intensity, and (C) treatment elements. For each topic, background information, clinical recommendations, and the basis for those recommendations are provided. As described in Chapter 1, each recommendation was given a strength of evidence classification based on the criteria shown in Table 7. Finally, for some topics, recommendations for further research are provided.

Table 7. Summary of strength of evidence for recommendations

Strength of evidence classification | Criteria
Strength of Evidence = A | Multiple well-designed randomized clinical trials, directly relevant to the recommendation, yielded a consistent pattern of findings.
Strength of Evidence = B | Some evidence from randomized clinical trials supported the recommendation, but the scientific support was not optimal. For instance, few randomized trials existed, the trials that did exist were somewhat inconsistent, or the trials were not directly relevant to the recommendation.
Strength of Evidence = C | Reserved for important clinical situations where the panel achieved consensus on the recommendation in the absence of relevant randomized controlled trials.

## A. Screening and Assessment

### Screen for Tobacco Use

Recommendation: All patients should be asked if they use tobacco and should have their tobacco- use status documented on a regular basis. Evidence has shown that this significantly increases rates of clinician intervention. (Strength of Evidence = A)

Recommendation: Clinic screening systems such as expanding the vital signs to include tobacco- use status, or the use of other reminder systems such as chart stickers or computer prompts are essential for the consistent assessment, documentation, and intervention with tobacco use. (Strength of Evidence =B)

A thorough review of articles published since the end-date of the original guideline literature review (December 31, 1994), revealed no studies that met criteria for the screening meta-analyses. Therefore, the panel decided to rely on the meta-analyses from the original guideline to determine the impact of tobacco screening systems. Such screening systems were evaluated in terms of their impact on two outcomes: the rate of tobacco cessation intervention by clinicians, and the rate of cessation by patients who smoke.

#### Identifying Tobacco Users: Impact on Clinical Intervention

Nine studies met the selection criteria from the original guideline and were analyzed using a random-effects meta-analysis to assess the impact of screening systems on the rate of smoking cessation intervention by clinicians. The results of this meta-analysis are shown in Table 8. Implementing clinic systems designed to increase the assessment and documentation of tobacco use status markedly increases the rate at which clinicians intervene with their patients who smoke.

Table 8. Meta-analysis: Impact of having a tobacco use status identification system in place on rates of clinician intervention with their patients who smoke (n = 9 studies)

Screening system | Number of arms | Estimated odds ratio (95% C.I.) | Estimated intervention rate (95% C.I.)
No screening system in place to identify smoking status (reference group) | 9 | 1.0 | 38.5
Screening system in place to identify smoking status | 9 | 3.1 (2.2-4.2) | 65.6 (58.3-72.6)

#### Identifying Tobacco Users: Impact on Tobacco Cessation

Three studies met the selection criteria from the original guideline and were analyzed using a random-effects meta-analysis to assess the impact of identifying smokers on actual rates of smoking cessation. The results of this meta- analysis are shown in Table 9. These results suggest that having a clinic system in place that identifies smokers results in higher rates of smoking cessation, although this finding was not statistically significant and was based on a small number of studies.

Table 9. Meta-analysis: Impact of having a tobacco use status identification system in place on abstinence rates among patients who smoke (n = 3 studies)

Screening system | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
No screening system in place to identify smoking status (reference group) | 3 | 1.0 | 3.1
Screening system in place to identify smoking status | 3 | 2.0 (0.8-4.8) | 6.4 (1.3-11.6)

Brief Strategy A1 (see Chapter 3A) and Systems Strategy A1 (see Chapter 5) detail an approach for including tobacco-use status as a vital sign with systematic prompts and reminders. Although the data assessing this intervention were exclusively gathered from cigarette smokers, the panel felt that these results were generalizable to all tobacco users. This approach is designed to produce consistent assessment and documentation of tobacco use. Evidence from controlled trials shows that this approach increases the probability that tobacco use is consistently assessed and documented.^12,^ ^81,^ ^82,^ ^83,^ ^84,^ ^85^

### Future Research

The following topic regarding screening for tobacco use requires additional research:

Additional evidence regarding the impact of screening systems on tobacco abstinence rates.

### Specialized Assessment

Recommendation: Once a tobacco user is identified and advised to quit, the clinician should assess the patient's willingness to quit at this time. (Strength of Evidence = C)

If the patient is willing to make a quit attempt at this time, interventions identified as effective in this guideline should be initiated. (see Chapter 3A and 4)

If the patient is unwilling to quit at this time, a motivational intervention should be provided. (see Chapter 3B)

Recommendation: Tobacco dependence treatment is effective and should be delivered even if specialized assessments are not used or available. (Strength of Evidence = A)

Every individual entering a health care setting should receive an assessment that determines his or her tobacco use status and interest in quitting. The patient should be asked, "Are you willing to make a quit attempt at this time?" Such an assessment (willing or unwilling) is a necessary first step in treatment. In addition, every patient should be assessed for physical or medical conditions that may affect the use of planned treatments (e.g., pharmacotherapy).

The clinician also may want to perform specialized assessments of individual and environmental attributes that provide information for tailoring treatment and that predict quitting success. Specialized assessments refer to the use of formal instruments (e.g., questionnaires, clinical interviews, or physiologic indices such as carbon monoxide, serum nicotine/cotinine levels, and/or pulmonary function) that may be associated with cessation outcome. Some of the variables targeted by specialized assessments that predict quitting success are listed in Table 10.

Table 10. Variables associated with higher or lower abstinence rates

Variables associated with higher abstinence rates
Variable | Examples
High motivation | Tobacco user reports motivation to quit.
Ready to change | Tobacco user is ready to quit within a 1-month period.
Moderate to high self-efficacy | Tobacco user is confident in his or her ability to quit.
Supportive social network | A smoke-free workplace and home; friends who do not smoke in the quitter's presence.
Variables associated with lower abstinence rates
Variable | Examples
High nicotine dependence | Tobacco user has had severe withdrawal during previous quit attempts, smokes heavily (>20 cigarettes/day), and/or has first cigarette of the day within 30 minutes after waking in the morning.
History of psychiatric comorbidity | Tobacco user has a history of depression, schizophrenia, alcoholism, or other chemical dependency.
High stress level | Stressful life circumstances and/or recent or anticipated major life changes (e.g., divorce, job change, and marriage)

Several considerations should be kept in mind regarding the use of specialized assessments. First, there is little consistent evidence that a smoker's status on a specialized assessment is useful for treatment matching. The one exception is that persons highly nicotine dependent may benefit more from 4 mg as opposed to 2 mg nicotine gum (see Chapter 6C, Pharmacotherapy). More importantly, the panel found that, regardless of their standing on specialized assessments, all smokers have the potential to benefit from cessation interventions. Therefore, delivery of tobacco dependence treatments should not depend on the use of specialized assessments. Finally, tailored interventions based on specialized assessments (e.g., stages of change) do not consistently produce higher long-term quit rates than do nontailored interventions of equal intensity. There do exist, however, some promising studies, which suggest that individualizing self-help materials may be beneficial.^86,^ ^87^ However, more studies are needed that contrast individualized self-help interventions with nonindividualized interventions of equivalent intensity. In addition, the panel recognizes that some effective interventions, such as general problemsolving (see Chapter 6C, Types of Counseling and Behavioral Therapies), entail treatment tailoring based on a systematic assessment of individual patient characteristics.

The existing evidence suggests that treatment can be effective despite the presence of risk factors for relapse (e.g., severe previous withdrawal, depression, other smokers in the home), but abstinence rates in smokers with these characteristics tend to be lower than rates in those without these characteristics.^88,^ ^89,^ ^90,^ ^91,^ ^92,^

### Future Research

The following topic regarding specialized assessment requires additional research:

Whether treatment adjustment based on specialized assessments can improve long-term abstinence rates.

## B. Treatment Structure and Intensity

### Advice To Quit Smoking

Recommendation: All physicians should strongly advise every patient who smokes to quit because evidence shows that physician advice to quit smoking increases abstinence rates. (Strength of Evidence = A)

Recommendation: All clinicians should strongly advise their patients who use tobacco to quit. Although studies have not independently addressed the impact of advice to quit by all types of nonphysician clinicians, it is reasonable to believe that such advice is effective in increasing their patients' long-term quit rates. (Strength of Evidence = B)

A thorough literature review identified no new studies since 1994 that examined the efficacy of advice to quit and that met the inclusion criteria for analysis. Therefore, the panel decided to rely on the analysis from the original guideline. Seven studies were included in the meta-analysis of the efficacy of physician advice to quit smoking. In the studies used in this analysis, the modal length of clinician intervention was 3 minutes or less. Two studies in this analysis used interventions lasting about 5 minutes. Results of the meta-analysis on physician advice are shown in Table 11. This analysis shows that brief physician advice significantly increases long-term smoking abstinence rates.

Table 11. Meta-analysis: Efficacy of and estimated abstinence rates for advice to quit by a physician (n = 7 studies)

Advice | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
No advice to quit (reference group) | 9 | 1.0 | 7.9
Physician advice to quit | 10 | 1.3 (1.1-1.6) | 10.2 (8.5-12.0)

Physician advice only was examined in the Table 11 meta-analysis because there were too few studies to examine advice delivered by any other types of clinicians. The analysis for total amount of contact time (see Table 13 provided in the following subsection) indicates that minimal counseling (advice) delivered by a variety of clinician types increase long-term abstinence rates. Also, it should be noted that studies have shown that dentists and dental hygienists can be effective in assessing and advising patients who use smokeless/spit tobacco to quit (see Chapter 8). Given the large number of smokers who visit a clinician each year, the potential public health impact of universal advice to quit is substantial.

Table 13. Meta-analysis: Efficacy of and estimated abstinence rates for total amount of contact time (n = 35 studies)

Total amount of contact time | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
No minutes | 16 | 1.0 | 11.0
1-3 minutes | 12 | 1.4 (1.1, 1.8) | 14.4 (11.3, 17.5)
4-30 minutes | 20 | 1.9 (1.5, 2.3) | 18.8 (15.6, 22.0)
31-90 minutes | 16 | 3.0 (2.3, 3.8) | 26.5 (21.5, 31.4)
91-300 minutes | 16 | 3.2 (2.3, 4.6) | 28.4 (21.3, 35.5)
>300 minutes | 15 | 2.8 (2.0, 3.9) | 25.5 (19.2, 31.7)

### Future Research

The following topics regarding advice to quit require additional research:

The efficacy of advice to quit smoking given by specific nonphysician clinicians such as nurses, psychologists, pharmacists, dentists, and dental hygienists.

The cumulative efficacy of combined advice from physicians and nonphysician providers.

### Intensity of Clinical Interventions

Recommendation: Minimal interventions lasting less than 3 minutes increase overall tobacco abstinence rates. Every tobacco user should be offered at least a minimal intervention whether or not he or she is referred to an intensive intervention. (Strength of Evidence = A)

Recommendation: There is a strong dose-response relation between the session length of person- to-person contact and successful treatment outcomes. Intensive interventions are more effective than less intensive interventions and should be used whenever possible. (Strength of Evidence = A)

Recommendation: Person-to-person treatment delivered for four or more sessions appears especially effective in increasing abstinence rates. Therefore, if feasible, clinicians should strive to meet four or more times with individuals quitting tobacco use. (Strength of Evidence = A)

These recommendations are supported by three separate analyses, one involving session length, one involving total amount of contact time, and one involving the number of sessions.

#### Session Length

Forty-three studies met selection criteria for comparisons among various session lengths. Whenever possible, session length was categorized based on the maximum amount of time the clinician spent with a smoker addressing tobacco dependence in a single contact. Minimal counseling interventions were defined as 3 minutes or less, low intensity counseling was defined as greater than 3 minutes to 10 minutes, and higher intensity counseling interventions were defined as greater than 10 minutes. Interventions could involve multiple patient-clinician contacts with the session length determined for coding purposes as the length of time of the longest session. These levels of person-to-person contact were compared with a no-contact reference group involving study conditions where subjects received no person-to-person contact (e.g., self-help-only conditions). There is a dose-response relation between session length and abstinence rates. As Table 12 shows, all three session lengths (minimal counseling, low intensity counseling, and higher intensity counseling) significantly increased abstinence rates over those produced by no-contact conditions. However, there was a clear trend for abstinence rates to increase across these session lengths, with higher intensity counseling producing abstinence rates that were significantly higher than the rates produced by minimal or low intensity counseling.

Table 12. Meta-analysis: Efficacy of and estimated abstinence rates for various intensity levels of person-to-person contact (n = 43 studies)

Level of contact | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
No contact | 30 | 1.0 | 10.9
Minimal counseling (< 3 minutes) | 19 | 1.3 (1.01, 1.6) | 13.4 (10.9, 16.1)
Low intensity counseling (3—10 minutes) | 16 | 1.6 (1.2, 2.0) | 16.0 (12.8, 19.2)
Higher intensity counseling (> 10 minutes) | 55 | 2.3 (2.0, 2.7) | 22.1 (19.4, 24.7)

#### Total Amount of Contact Time

Thirty-five studies met the selection criteria for the analysis assessing the impact of total contact time. The amount of contact time was calculated from the text as the total time accumulated (the number of sessions multiplied by the session length). When the exact time was not known for minimal and low intensity interventions, they were assigned median lengths of 2 and 6.5 minutes respectively. The total amount of contact time was then categorized as no-contact, 1-3 minutes, 4-30 minutes, 31-90 minutes, 91-300 minutes, and greater than 300 minutes. There is a dose-response relation between total amount of contact time and abstinence rates. As Table 13 shows, any contact time significantly increased abstinence rates over those produced by no-contact. However, there was a clear trend for abstinence rates to increase across contact time, with 31-90 minutes producing abstinence rates that were significantly higher than the rates produced by 1-3 minutes of total contact time. There was no evidence that more than 90 minutes of contact time increases abstinence rates further.

#### Number of Sessions

Forty-five studies involving at least some person-to-person contact met selection criteria for the analysis addressing the impact of number of treatment sessions. The number of treatment sessions was categorized as zero or one session, two to three sessions, four to eight sessions, and greater than eight sessions. Zero or one session was used as the reference group. As shown in Table 14, multiple treatment sessions increase smoking abstinence rates over those produced by zero or one session. The evidence suggests a dose-response relation between number of sessions and treatment efficacy, with treatments lasting more than 8 sessions significantly more effective than interventions lasting either zero to one or two to three sessions.

Table 14. Meta-analysis: Efficacy of and estimated abstinence rates for number of person-to-person treatment sessions (n = 45 studies)

Number of sessions | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
0-1 session | 43 | 1.0 | 12.4
2-3 sessions | 17 | 1.4 (1.1, 1.7) | 16.3 (13.7, 19.0)
4-8 sessions | 23 | 1.9 (1.6, 2.2) | 20.9 (18.1, 23.6)
> 8 sessions | 51 | 2.3 (2.1, 3.0) | 24.7 (21.0, 28.4)

### Future Research

The following topics regarding intensity of person-to-person contact require additional research:

The effects of treatment duration and spacing of sessions (i.e., the number of days or weeks over which treatment is spread). For instance, does front-loading sessions (having the majority of the sessions during the first few weeks of a quit attempt), or spacing sessions throughout the quit attempt yield better long-term abstinence rates?

Methods to increase the patient utilization and completion of intensive treatments.

Efficacy of intensive inpatient treatment programs.

### Type of Clinician

Recommendation: Treatment delivered by a variety of clinician types increases abstinence rates. Therefore, all clinicians should provide smoking cessation interventions. (Strength of Evidence = A)

Recommendation: Treatments delivered by multiple types of clinicians are more effective than interventions delivered by a single type of clinician. Therefore, if feasible, the delivery of interventions by more than one type of clinician is encouraged. (Strength of Evidence = C)

#### Clinician Types

Twenty-nine studies met selection criteria for the analysis examining the effectiveness of various types of clinicians providing smoking cessation interventions. These analyses compared the efficacy of interventions delivered by specific types of clinicians with interventions where there were no clinicians (e.g., where there was no intervention or the intervention consisted of self-help materials only). Smoking cessation interventions delivered by any single type of health care provider, such as a physician or nonphysician clinician (e.g., psychologist, nurse, dentist, or counselor), or by multiple clinicians, increase abstinence rates relative to interventions where there is no clinician (e.g., self-help interventions). None of the studies in these analyses involved pharmacotherapy, but they did involve psychosocial intervention of varying intensities. Results are shown in Table 15. Results are consistent across diverse clinician groups, with no clear advantage to any single clinician type.

Table 15. Meta-analysis: Efficacy of and estimated abstinence rates for interventions delivered by various types of clinicians (n = 29 studies)

Type of clinician | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
No clinician | 16 | 1.0 | 10.2
Self-help | 47 | 1.1 (0.9, 1.3) | 10.9 (9.1, 12.7)
Nonphysician clinician | 39 | 1.7 (1.3, 2.1) | 15.8 (12.8, 18.8)
Physician clinician | 11 | 2.2 (1.5, 3.2) | 19.9 (13.7, 26.2)

#### Number of Clinician Types

Thirty-seven studies met selection criteria for the analysis examining the effectiveness of multiple clinicians used in smoking cessation interventions. Please note that "multiple clinicians" refers to the number of different types of clinicians, not the number of total clinicians regardless of type. The latter information was rarely available from the study reports. Smoking cessation interventions delivered by multiple types of clinicians increase abstinence rates relative to those produced by interventions where there is no clinician. Results are shown in Table 16. The data displayed in Table 16 also show a nonsignificant trend for multiple types of clinicians to be more efficacious than a single clinician type. This suggests that a variety of clinicians, including physician clinicians, and nonphysician clinicians, such as nurses, dentists, dental hygienists, psychologists, pharmacists, and health educators, can play an important role in promoting smoking cessation.

Table 16. Meta-analysis: Efficacy of and estimated abstinence rates for interventions delivered by various numbers of clinician types (n = 37 studies)

Number of clinician types | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
No clinician | 30 | 1.0 | 10.8
One clinician type | 50 | 1.8 (1.5, 2.2) | 18.3 (15.4, 21.1)
Two clinician types | 16 | 2.5 (1.9, 3.4) | 23.6 (18.4, 28.7)
Three or more clinician types | 7 | 2.4 (2.1, 2.9) | 23.0 (20.0, 25.9)

### Future Research

The following topics regarding type of clinician require additional research:

The effectiveness of specific types of clinicians, such as nurses, physician assistants, pharmacists, social workers, etc.

The relative effectiveness of various numbers and types of clinicians, with the intensity of the intervention held constant.

Strategies to integrate tobacco dependence treatment across diverse disciplines and settings.

### Formats of Psychosocial Treatments

Recommendation: Proactive telephone counseling, and group and individual counseling formats are effective and should be used in smoking cessation interventions. (Strength of Evidence = A)

Recommendation: Smoking cessation interventions that are delivered in multiple formats increase abstinence rates and should be encouraged. (Strength of Evidence = A)

#### Format Types

Fifty-eight studies met selection criteria and were included in the analysis comparing different types of formats. Smoking cessation interventions delivered by means of proactive telephone counseling/contact, individual counseling, and group counseling/contact all increase abstinence rates relative to no intervention.

This format meta-analysis also evaluated the efficacy of self-help interventions (e.g., pamphlets/booklets/mailings/manuals, videotapes, audiotapes, referrals to 12-step programs, mass media community level interventions, reactive telephone hotlines/helplines, computer programs/Internet, and lists of community programs). Interventions delivered by means of widely varied self-help materials (whether as stand-alone treatments or as adjuvants) appear to increase abstinence rates relative to no intervention in this particular analysis. However, the effect of self- help is weak and inconsistent across analyses conducted for this guideline. The impact of self-help is certainly smaller and less certain than that of proactive telephone, individual, or group counseling. Results of this analysis are shown in Table 17.

Table 17. Meta-analysis: Efficacy of and estimated abstinence rates for various types of format (n = 58 studies)

Format | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
No format | 20 | 1.0 | 10.8
Self-help | 93 | 1.2 (1.02, 1.3) | 12.3 (10.9, 13.6)
Proactive telephone counseling | 26 | 1.2 (1.1, 1.4) | 13.1 (11.4, 14.8)
Group counseling | 52 | 1.3 (1.1, 1.6) | 13.9 (11.6, 16.1)
Individual counseling | 67 | 1.7 (1.4, 2.0) | 16.8 (14.7, 19.1)

#### Number of Formats

Fifty-four studies met selection criteria and were included in the analysis comparing the number of format types used for smoking cessation interventions. The self-help treatments included in this analysis occurred either by themselves or as adjuvants to other treatments. Smoking cessation interventions that used more than two format types were more effective than interventions that used a single format type. Results of this analysis are shown in Table 18.

Table 18. Meta-analysis: Efficacy of and estimated abstinence rates for number of formats (n = 54 studies)

Number of formats ^a^ | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
No format | 20 | 1.0 | 10.8
One format | 51 | 1.5 (1.2, 1.8) | 15.1 (12.8, 17.4)
Two formats | 55 | 1.9 (1.6, 2.2) | 18.5 (15.8, 21.1)
Three or four formats | 19 | 2.5 (2.1, 3.0) | 23.2 (19.9, 26.6)

a Formats included self-help, proactive telephone counseling, group, or individual counseling.

#### Self-help: focused analyses

Because the format analysis revealed self-help to be of marginal efficacy, another analysis was undertaken to provide additional, focused information on self-help. Studies were accepted for this analysis if the presence of self-help materials constituted the sole difference in treatment arms. In the main format analysis, some treatment arms differed on factors other than self-help per se (e.g., intensity of adjuvant counseling). The treatments that accompanied self-help material in the focused analysis ranged from no advice or counseling to intensive counseling. The results of this analysis were comparable to those in the larger format analysis (i.e., self-help was of marginal efficacy).

Twenty-one studies met selection criteria to evaluate the efficacy of providing multiple types of self- help interventions (e.g., pamphlets, videotapes, audiotapes, and reactive hotlines/helplines). The results provide little evidence that the provision of multiple types of self-help, when offered without any person-to-person intervention, significantly enhances treatment outcomes (see Table 19).

Table 19. Meta-analysis: Efficacy of and estimated abstinence rates for number of types of self-help (n = 21 studies)

Factor | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
No self-help | 17 | 1.0 | 14.3
One type of self-help | 27 | 1.0 (0.9, 1.1) | 14.4 (12.9, 15.9)
Two or more types | 10 | 1.1 (0.9, 1.5) | 15.7 (12.3, 19.2)

There are two limitations to interpreting these results. First, self-help materials vary greatly in nature and intensity. It is possible that some sub-types of self-help are, in fact, efficacious (e.g., those that are individualized). Second, a large number of smokers report that they quit on their own without clinical support or contact.^93^ The extent to which use of self-help materials aids self- quitters was not addressed in guideline analyses.

The previous analyses failed to show a consistent, beneficial effect due to self-help. Two final meta- analyses addressed the impact of self-help brochures per se. In one analysis, brochures were used as the only intervention. In the other analysis, self-help brochures were used as adjuvants to counseling. In neither analysis did self-help significantly boost abstinence rates.

### Future Research

The following topics regarding formats require additional research:

Identify which combinations of formats are effective.

The efficacy of innovative approaches to self-help such as individualized computerized interventions.^87,^ ^94,^ ^95^

The efficacy of reactive telephone hotlines/helplines.^60,^ ^96,^ ^97,^ ^98,^ ^99^

The relative efficacy of different types of self-help interventions.

The efficacy of self-help materials as adjuvant treatments. Do they add significantly to the effectiveness of other proven tobacco dependence treatments such as individual counseling, group counseling, proactive telephone counseling, and pharmacotherapy?

### Followup Assessment and Procedures

Recommendation: All patients who receive a tobacco dependence intervention should be assessed for abstinence at the completion of treatment and during subsequent clinic contacts. (1) Abstinent patients should receive relapse prevention treatment (see Chapter 3C, For the Patient Who Has Quit). (2) Patients who have relapsed should be assessed to determine whether they are willing to make another quit attempt. (Strength of Evidence = C):

If the patient is willing to make another quit attempt, provide or arrange additional treatment (see Chapter 3A, For the Patient Willing To Quit).

If the patient is not willing to try to quit, provide an intervention to promote motivation to quit (see Chapter 3B, For the Patient Unwilling To Quit).

All patients should be assessed with respect to their smoking status during all followup tobacco dependence contacts. In particular, assessments within the first week after quitting also should be encouraged.^100^ Abstinent patients should receive relapse prevention treatment (see Chapter 3C, Brief Strategy C1 and Brief Strategy C2) including reinforcement for their decision to quit, congratulations on their success at quitting, and encouragement to remain abstinent.^62^ Clinicians also should inquire about current and future threats to abstinence and provide appropriate suggestions for coping with these threats.

Patients who have relapsed should again be assessed for their willingness to quit. Patients who are currently motivated to make another quit attempt should be provided with a tobacco dependence intervention (see Chapter 3A, For the Patient Willing To Quit). Clinicians may wish to increase the intensity of psychosocial treatment at this time or refer the patient to a tobacco dependence specialist/program for a more intensive treatment if the patient is willing. In addition, pharmacotherapy should be again offered to the patient. If the previous cessation attempt included pharmacotherapy, the clinician should review whether the patient used these medications in an effective manner and determine whether the medication was helpful. Based on this assessment, recommend retreatment with the same pharmacotherapy, another pharmacotherapy, or combination nicotine replacement therapies (see Tables 33-39).

Patients who are unwilling to quit at the current time should receive a brief intervention designed to promote the motivation to quit (see Chapter 3B, Brief Strategy B. Enhancing motivation to quit tobacco-the "5 R's").

### Future Research

The following topics regarding followup assessment require additional research:

The optimal timing and types of relapse prevention interventions.

The efficacy of various formats for relapse prevention treatments. For instance, are telephone contacts effective in reducing the likelihood of relapse after a minimal intervention?

## C. Treatment Elements

### Types of Counseling and Behavioral Therapies

Recommendation: Three types of counseling and behavioral therapies result in higher abstinence rates: (1) providing smokers with practical counseling (problemsolving skills/skills training); (2) providing social support as part of treatment; and (3) helping smokers obtain social support outside of treatment. These types of counseling and behavioral therapies should be included in smoking cessation interventions. (Strength of Evidence = B)

Recommendation: Aversive smoking interventions (rapid smoking, rapid puffing, other aversive smoking techniques) increase abstinence rates and may be used with smokers who desire such treatment or who have been unsuccessful using other interventions. (Strength of Evidence = B)

Sixty-two studies met selection criteria for analyses examining the effectiveness of interventions using various types of counseling and behavioral therapies. The results, shown in Table 20, reveal that four specific types of counseling and behavioral therapy categories yield statistically significant increases in abstinence rates relative to no-contact (e.g., untreated control conditions). These categories are: (1) providing practical counseling such as problemsolving/skills training/relapse prevention/stress management; (2) providing support during a smoker's direct contact with a clinician (intra-treatment social support); (3) intervening to increase social support in the smoker's environment (extra-treatment social support); and (4) using aversive smoking procedures (rapid smoking, rapid puffing, other smoking exposure). A separate analysis was conducted eliminating studies that included the use of FDA-approved pharmacotherapies. The results of this analysis were substantially similar to the main analysis.

Table 20. Meta-analysis: Efficacy of and estimated abstinence rates for various types of counseling and behavioral therapies (n = 62 studies)

Type of counseling and behavioral therapy | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
No counseling/ behavioral therapy | 35 | 1.0 | 11.2
Relaxation/breathing | 31 | 1.0 (0.7, 1.3) | 10.8 (7.9, 13.8)
Contingency contracting | 22 | 1.0 (0.7, 1.4) | 11.2 (7.8, 14.6)
Weight/diet | 19 | 1.0 (0.8, 1.3) | 11.2 (8.5, 14.0)
Cigarette fading | 25 | 1.1 (0.8, 1.5) | 11.8 (8.4, 15.3)
Negative affect | 8 | 1.2 (0.8, 1.9) | 13.6 (8.7, 18.5)
Intra-treatment social support | 50 | 1.3 (1.1, 1.6) | 14.4 (12.3, 16.5)
Extra-treatment social support | 19 | 1.5 (1.1, 2.1) | 16.2 (11.8, 20.6)
General—problemsolving | 104 | 1.5 (1.3, 1.8) | 16.2 (14.0, 18.5)
Other aversive smoking | 19 | 1.7 (1.04, 2.8) | 17.7 (11.2, 24.9)
Rapid smoking | 19 | 2.0 (1.1, 3.5) | 19.9 (11.2, 29.0)

The strength of evidence for the recommendations regarding types of counseling and behavioral therapy categories did not warrant an "A" rating for several reasons. First, smoking cessation interventions rarely used a particular type of counseling or behavioral therapy in isolation. Second, various types of counseling and behavioral therapies tended to be correlated with other treatment characteristics. For instance, some types of counseling and behavioral therapies were more likely to be delivered using a greater number of sessions across longer time periods. Third, it must be noted that all of these types of counseling and behavioral therapies were compared with no- contact/control conditions. Therefore, the control conditions in this meta-analysis did not control for nonspecific or placebo effects of treatment. This further restricted the ability to attribute efficacy to particular types of counseling and behavioral therapies, per se. Fourth, the studies used in this analysis often tailored the types of counseling and behavioral therapies to the needs of special populations being studied, thereby affecting the generalizability of the study results. Fifth, there was considerable heterogeneity within each type of counseling and behavioral therapy.

In the types of counseling and behavioral therapies meta-analysis, six studies examined the effect of dieting and physical activity interventions on smoking cessation. Although dieting and physical activity did not significantly increase abstinence rates based on that analysis, a single recent study published after the date for inclusion in meta-analysis found that vigorous exercise did boost quit rates.^101^

The treatments targeting negative affect were administered both to general populations as well as to special populations (e.g., smokers with a history of depression).^102,^ ^103^ It is possible that different results would have been found if the study arms were restricted to smokers at risk for negative affect.

Tables 21, 22, and 23 outline elements of practical counseling (problemsolving/skills training), intra- treatment social support, and extra-treatment social support respectively. These tables are designed to help clinicians using these counseling and behavioral therapies. It must be noted, however, that these treatment labels are nonspecific and include heterogeneous treatment elements.

Table 21. Common elements of practical counseling (problemsolving/ skills training)

Practical counseling (problemsolving/skills training) treatment component | Examples
Recognize danger situations -- Identify events, internal states, or activities that increase the risk of smoking or relapse. | - Negative affect.; - Being around other smokers.; - Drinking alcohol.; - Experiencing urges.; - Being under time pressure.
Develop coping skills -- Identify and practice coping or problemsolving skills. Typically, these skills are intended to cope with danger situations. | - Learning to anticipate and avoid temptation.; - Learning cognitive strategies that will reduce negative moods.; - Accomplishing lifestyle changes that reduce stress, improve quality of life, or produce pleasure.; - Learning cognitive and behavioral activities to cope with smoking urges (e.g., distracting attention).
Provide basic information -- provide basic information about smoking and successful quitting. | - The fact that any smoking (even a single puff) increases the likelihood of a full relapse.; - Withdrawal typically peaks within 1-3 weeks after quitting.; - Withdrawal symptoms include negative mood, urges to smoke, and difficulty concentrating.; - The addictive nature of smoking.

Table 22. Common elements of intra-treatment supportive interventions

Supportive treatment component | Examples
Encourage the patient in the quit attempt. | - Note that effective tobacco dependence treatments are now available.; - Note that one-half of all people who have ever smoked have now quit.; - Communicate belief in patient's ability to quit.
Communicate caring and concern. | - Ask how patient feels about quitting.; - Directly express concern and willingness to help.; - Be open to the patient's expression of fears of quitting, difficulties experienced, and ambivalent feelings.
Encourage the patient to talk about the quitting process. | Ask about:; - Reasons the patient wants to quit.; - Concerns or worries about quitting.; - Success the patient has achieved.; - Difficulties encountered while quitting.

Table 23. Common elements of extra-treatment supportive interventions

Supportive treatment component | Examples
Train patient in support solicitation skills | - Show videotapes that model support skills.; - Practice requesting social support from family, friends, and coworkers.; - Aid patient in establishing a smoke-free home.
Prompt support seeking | - Help patient identify supportive others.; - Call the patient to remind him or her to seek support.; - Inform patients of community resources such as hotlines and helplines.
Clinician arranges outside support | - Mail letters to supportive others.; - Call supportive others.; - Invite others to cessation sessions.; - Assign patients to be "buddies" for one another.

Another type of behavioral therapy associated with superior outcomes is aversive smoking. This involves sessions of guided smoking where the patient smokes intensively, often to the point of discomfort, malaise, nausea, and/or vomiting. Some aversive smoking techniques, such as rapid smoking, may constitute a health risk and should be conducted only with appropriate medical screening and supervision. Aversive smoking interventions are infrequently used today.

#### Acupuncture

A separate meta-analysis was conducted for acupuncture. This analysis was conducted to achieve a sensitive test on the small body of studies that use this technique. Evidence, as shown in Table 24, did not support the efficacy of acupuncture as a smoking cessation treatment. The acupuncture meta-analysis comparing "active" acupuncture with "control" acupuncture revealed no difference in efficacy between the two types of procedures. These results suggest that any effect of acupuncture might be produced by factors such as positive expectations about the procedure.

Table 24. Meta-analysis: Efficacy of and estimated abstinence rates for acupuncture (n = 5 studies)

Treatment | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
Placebo | 7 | 1.0 | 8.3
Acupuncture | 8 | 1.1 (0.7, 1.6) | 8.9 (5.5, 12.3)

#### Hypnosis

The original guideline did not conduct a separate meta-analysis on hypnosis because few studies met inclusion criteria, and those that did used very heterogeneous hypnotic procedures. There was no common or standard intervention technique to analyze. Literature screening for the updated guideline revealed no new published studies on the treatment of tobacco dependence by hypnosis that met the inclusion criteria; therefore, this topic did not warrant re-examination. Moreover, an independent review of hypnotherapy trials by the Cochrane Group found insufficient evidence to support hypnosis as a treatment for smoking cessation.^104^

#### Other Interventions

There were insufficient studies to address the efficacy of other types of counseling and behavioral therapies such as physiological feedback and restricted environmental stimulation therapy.

### Future Research

The following topics regarding types of counseling and behavioral therapies require additional research:

- Motivational interventions, cigarette fading, hypnosis, physiological feedback of smoking impacts, 12-step models, and restricted environmental stimulation therapy.
- Mechanisms through which counseling interventions exert their effects.
- Efficacy of specific counseling interventions among various patient populations (e.g., those with cancers, chronic obstructive pulmonary disease (COPD), and atherosclerosis).

### Alternative Treatment Models for the Treatment of Tobacco Dependence—Stepped Care and Individual Tailoring

The panel concluded that there is not enough evidence to propose a recommendation regarding: (1) a stepped-care model for delivery of tobacco dependence treatment; and (2) individually tailored interventions (e.g., using the transtheoretical model). Both of these intervention strategies hold promise, and enjoy some empirical support. Tailored self-help approaches especially enjoy some support.^105,^ ^106,^ ^107^ Unfortunately, there is insufficient data to indicate that either approach yields a significant incremental impact on long-term abstinence rates over the impact of nontailored counseling approaches of similar intensity. As a result, there needs to be additional research to test the efficacy of these strategies. Some of the needed research includes:

- Whether the use of stepped-care intervention strategies improves long-term abstinence rates.
- Whether the use of treatment matching strategies improves long-term abstinence rates.
- Whether the use of tailored intervention strategies improves long-term abstinence rates.
- Whether targeted reductions in the number of cigarettes smoked per day increases long-term rates of abstinence.^108^
- Whether staged-based treatments developed in keeping with the transtheoretical model significantly improve long-term abstinence rates relative to comparably intense, alternative counseling strategies (e.g., where patients receive only a standard motivational treatment or cessation treatment depending on their willingness to quit).

### Pharmacotherapy

Recommendation: All patients attempting to quit should be encouraged to use effective pharmacotherapies for smoking cessation except in the presence of special circumstances. (Strength of Evidence = A)

Recommendation: Long-term smoking cessation pharmacotherapy should be considered as a strategy to reduce the likelihood of relapse. (Strength of Evidence = C)

As with other chronic diseases, the most effective treatment of tobacco dependence requires the use of multiple modalities. Pharmacotherapy is a vital element of a multicomponent approach. The clinician should encourage all patients initiating a quit attempt to use one or a combination of efficacious pharmacotherapies, although pharmacotherapy use requires special consideration with some patient groups (e.g., those with medical contraindications, those smoking fewer than 10 cigarettes a day, pregnant/breastfeeding women and adolescent smokers). The guideline panel identified five first-line medications (bupropion SR, nicotine gum, nicotine inhaler, nicotine nasal spray, and the nicotine patch) and two second-line medications (clonidine and nortriptyline) for smoking cessation. Each has been documented to increase significantly rates of long-term smoking abstinence. No other pharmacotherapeutic treatments were supported by a consistent body of scientific evidence.

The pharmacotherapy meta-analyses were designed to compare particular pharmacotherapies with the placebo controls in each study. Because of substantial differences across the studies evaluating the different types of pharmacotherapies, it is inappropriate to compare the results for one medication with those for another in the tables that follow.

Pharmacotherapy meta-analyses included predominately studies with "self-selected" populations. In addition, in pharmacotherapy studies both experimental and control subjects typically received substantial counseling. Both of these factors tend to produce higher abstinence rates in reference or placebo subjects than are typically observed among self-quitters.

## Recommendations Regarding Specific Pharmacotherapies: First-Line Medications

First-line pharmacotherapies have been found to be safe and effective for tobacco dependence treatment and have been approved by the U.S. Food and Drug Administration (FDA) for this use. First-line medications have established empirical record of efficacy, and should be considered first as part of tobacco dependence treatment except in cases of contraindications.

The listing of the first-line medications is provided alphabetically. Meta-analyses did not contrast the relative efficacy of these medications.

### Bupropion SR (Sustained Release Bupropion)

Recommendation: Bupropion SR is an efficacious smoking cessation treatment that patients should be encouraged to use. (Strength of Evidence = A)

Two large multicenter studies met selection criteria and were included in the analysis comparing bupropion sustained release (SR) to placebo. Results of this analysis are shown in Table 25. As can be seen from this analysis, the use of bupropion SR approximately doubles long-term abstinence rates when compared to a placebo.

Table 25. Meta-analysis: Efficacy of and estimated abstinence rates for bupropion SR (n = 2 studies)

Pharmacotherapy | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
Placebo | 2 | 1.0 | 17.3
Bupropion SR | 4 | 2.1 (1.5, 3.0) | 30.5 (23.2, 37.8)

Bupropion SR is the first non-nicotine medication shown to be effective for smoking cessation and approved by the FDA for that use. Its mechanism of action is presumed to be mediated by its capacity to block neural re-uptake of dopamine and/or norepinephrine. It is contraindicated in patients with a seizure disorder, a current or prior diagnosis of bulimia or anorexia nervosa, use of a monoamine oxidase (MAO) inhibitor within the previous 14 days, or in patients on another medication that contains bupropion. Bupropion SR can be used in combination with nicotine replacement therapies. Bupropion SR is available exclusively as a prescription medication both with an indication for smoking cessation (Zyban) and an indication for depression (Wellbutrin). Suggestions regarding the clinical use of bupropion SR are provided in Table 33.

Table 33. Suggestions for the clinical use of bupropion SR

| Clinical use of bupropion SR (FDA approved)
Patient selection | Appropriate as a first-line pharmacotherapy for smoking cessation.
Precautions | Pregnancy -- Pregnant smokers should be encouraged to quit first without pharmacologic treatment. Bupropion SR should be used during pregnancy only if the increased likelihood of smoking abstinence, with its potential benefits, outweighs the risk of bupropion SR treatment and potential concomitant smoking. Similar factors should be considered in lactating women. (FDA Class B) Cardiovascular diseases -- Generally well tolerated; infrequent reports of hypertension. Side effects -- The most common side effects reported by bupropion SR users were insomnia (35-40%) and dry mouth (10%). Contraindications -- Bupropion SR is contraindicated in individuals with a history of seizure disorder, a history of an eating disorder, who are using another form of bupropion (Wellbutrin or Wellbutrin SR), or who have used an MAO inhibitor in the past 14 days.
Dosage | Patients should begin with a dose of 150 mg q AM for 3 days, then increase to 150 mg b.i.d. Dosing at 150 mg b.i.d. should continue for 7-12 weeks following the quit date. Unlike nicotine replacement products, patients should begin bupropion SR treatment 1-2 weeks before they quit smoking. For maintenance therapy, consider bupropion SR 150 mg b.i.d. for up to 6 months.
Availability | Zyban -- Prescription only.
Prescribing instructions | Cessation prior to quit date -- Recognize that some patients will lose their desire to smoke prior to their quit date, or will spontaneously reduce the amount they smoke. Scheduling of dose -- If insomnia is marked, taking the PM dose earlier (in the afternoon, at least 8 hours after the first dose) may provide some relief. Alcohol -- Use alcohol only in moderation.
Cost/day ^a^ | $3.33

a Cost data is based on the retail price of the medication purchased at a national chain pharmacy located in Madison, WI April 2000.

### Nicotine Gum

Recommendation: Nicotine gum is an efficacious smoking cessation treatment that patients should be encouraged to use. (Strength of Evidence = A)

Recommendation: Clinicians should offer 4 mg rather than 2 mg nicotine gum to highly dependent smokers. (Strength of Evidence = B)

Thirteen studies met selection criteria and were included in the analysis comparing nicotine gum to placebo. Results of this analysis are shown in Table 26. As can be seen by the estimated odds ratio from this analysis, 2 mg nicotine gum improves long-term abstinence rates by approximately 30-80 percent as compared with placebo. Furthermore, a close review of the literature suggests that the 4 mg gum is more efficacious than the 2 mg gum as an aid to smoking cessation in highly dependent smokers (see Table 10. Variables associated with higher or lower abstinence rates).^109,^ ^110^

Table 26. Meta-analysis: Efficacy of and estimated abstinence rates for 2 mg nicotine gum (n = 13 studies)

Pharmacotherapy | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
Placebo | 16 | 1.0 | 17.1
Nicotine gum | 18 | 1.5 (1.3, 1.8) | 23.7 (20.6, 26.7)

Nicotine gum is currently available exclusively as an over-the-counter medication and is packaged with important instructions on correct usage, including chewing instructions. Suggestions regarding the clinical use of nicotine gum are provided in Table 34.

Table 34. Suggestions for the clinical use of nicotine gum

| Clinical use of nicotine gum (FDA approved)
Patient selection | Appropriate as a first-line pharmacotherapy for smoking cessation.
Precautions | Pregnancy -- Pregnant smokers should be encouraged to quit first without pharmacologic treatment. Nicotine gum should be used during pregnancy only if the increased likelihood of smoking abstinence, with its potential benefits, outweighs the risk of nicotine replacement and potential concomitant smoking. Similar factors should be considered in lactating women. (FDA Class D) Cardiovascular diseases -- NRT is not an independent risk factor for acute myocardial events. NRT should be used with caution among particular cardiovascular patient groups: those in the immediate (within 2 weeks) postmyocardial infarction period, those with serious arrhythmias, and those with serious or worsening angina pectoris. Side effects -- Common side effects of nicotine chewing gum include mouth soreness, hiccups, dyspepsia, and jaw ache. These effects are generally mild and transient, and often can be alleviated by correcting the patient's chewing technique (see prescribing instructions below).
Dosage | Nicotine gum is available in 2 mg and 4 mg (per piece) doses. The 2 mg gum is recommended for patients smoking less than 25 cigarettes per day, while the 4 mg gum is recommended for patients smoking 25 or more cigarettes per day. Generally, the gum should be used for up to 12 weeks with no more than 24 pieces/day. Clinicians should tailor the dosage and duration of therapy to fit the needs of each patient.
Availability | Nicorette, Nicorette Mint -- OTC only.
Prescribing instructions | Chewing technique -- Gum should be chewed slowly until a "peppery" or "minty" taste emerges, then "parked" between cheek and gum to facilitate nicotine absorption through the oral mucosa. Gum should be slowly and intermittently "chewed and parked" for about 30 minutes or until the taste dissipates. Absorption -- Acidic beverages (e.g., coffee, juices, soft drinks) interfere with the buccal absorption of nicotine, so eating and drinking anything except water should be avoided for 15 minutes before and during chewing. Scheduling of dose -- Patients often do not use enough gum to get the maximum benefit: they chew too few pieces per day and they do not use the gum for a sufficient number of weeks. Instructions to chew the gum on a fixed schedule (at least one piece every 1-2 hours) for at least 1-3 months may be more beneficial than ad libitum use.
Cost/day ^a^ | $6.25 for 10, 2 mg pieces. $6.87 for 10, 4 mg pieces.

a Cost data is based on the retail price of the medication purchased at a national chain pharmacy located in Madison, WI April 2000.

### Nicotine Inhaler

Recommendation: The nicotine inhaler is an efficacious smoking cessation treatment that patients should be encouraged to use. (Strength of Evidence = A)

Four studies met selection criteria and were included in the analysis comparing the nicotine inhaler to placebo. Results of this analysis are shown in Table 27. As can be seen from this analysis, the nicotine inhaler more than doubles long-term abstinence rates when compared to a placebo inhaler.

Table 27. Meta-analysis: Efficacy of and estimated abstinence rates for nicotine inhaler (n = 4 studies)

Pharmacotherapy | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
Placebo | 4 | 1.0 | 10.5
Nicotine inhaler | 4 | 2.5 (1.7, 3.6) | 22.8 (16.4, 29.2)

The nicotine inhaler is available exclusively as a prescription medication. Suggestions regarding the clinical use of the nicotine inhaler are provided in Table 35.

Table 35. Suggestions for the clinical use of the nicotine inhaler

| Clinical use for the nicotine inhaler (FDA approved)
Patient selection | Appropriate as a first-line pharmacotherapy for smoking cessation.
Precautions | Pregnancy—Pregnant smokers should be encouraged to quit first without pharmacologic treatment. The nicotine inhaler should be used during pregnancy only if the increased likelihood of smoking abstinence, with its potential benefits, outweighs the risk of nicotine replacement and potential concomitant smoking. Similar factors should be considered in lactating women. (FDA Class D) Cardiovascular diseases -- NRT is not an independent risk factor for acute myocardial events. NRT should be used with caution among particular cardiovascular patient groups: those in the immediate (within 2 weeks) postmyocardial infarction period, those with serious arrhythmias, and those with serious or worsening angina pectoris. Local irritation reactions -- Local irritation in the mouth and throat was observed in 40% of patients using the nicotine inhaler. Coughing (32%) and rhinitis (23%) also were common. Severity was generally rated as mild, and the frequency of such symptoms declined with continued use.
Dosage | A dose from the nicotine inhaler consists of a puff or inhalation. Each cartridge delivers 4 mg of nicotine over 80 inhalations. Recommended dosage is 6-16 cartridges/day. Recommended duration of therapy is up to 6 months. Instruct patient to taper dosage during the final 3 months of treatment.
Availability | Nicotrol Inhaler -- prescription only
Prescribing instructions | Ambient temperature -- Delivery of nicotine from the inhaler declines significantly at temperatures below 40°F. In cold weather, the inhaler and cartridges should be kept in an inside pocket or warm area. Duration -- Use is recommended for up to 6 months with gradual reduction in frequency of use over the last 6-12 weeks of treatment. Absorption -- Acidic beverages (e.g., coffee, juices, soft drinks) interfere with the buccal absorption of nicotine, so eating and drinking anything except water should be avoided for 15 minutes before and during inhalation. Best effects -- Best effects are achieved by frequent puffing.
Cost/day ^a^ | $10.94 for 10 cartridges.

a Cost data is based on the retail price of the medication purchased at a national chain pharmacy located in Madison, WI April 2000.

### Nicotine Nasal Spray

Recommendation: Nicotine nasal spray is an efficacious smoking cessation treatment that patients should be encouraged to use. (Strength of Evidence = A)

Three studies met selection criteria and were included in the analysis comparing nicotine nasal spray to placebo. Results of this analysis are shown in Table 28. As can be seen from this analysis, nicotine nasal spray more than doubles long-term abstinence rates when compared to a placebo spray.

Table 28. Meta-analysis: Efficacy of and estimated abstinence rates for nicotine nasal spray (n = 3 studies)

Pharmacotherapy | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
Placebo | 3 | 1.0 | 13.9
Nicotine nasal spray | 3 | 2.7 (1.8, 4.1) | 30.5 (21.8, 39.2)

Nicotine nasal spray is available exclusively as a prescription medication. Suggestions regarding the clinical use of the nicotine nasal spray are provided in Table 36.

Table 36. Suggestions for the clinical use of the nicotine nasal spray

| Clinical use for nicotine nasal spray (FDA approved)
Patient selection | Appropriate as a first-line pharmacotherapy for smoking cessation.
Precautions | Pregnancy -- Pregnant smokers should be encouraged to quit first without pharmacologic treatment. Nicotine nasal spray should be used during pregnancy only if the increased likelihood of smoking abstinence, with its potential benefits, outweighs the risk of nicotine replacement and potential concomitant smoking. Similar factors should be considered in lactating women. (FDA Class D) Cardiovascular diseases -- NRT is not an independent risk factor for acute myocardial events. NRT should be used with caution among particular cardiovascular patient groups: those in the immediate (within 2 weeks) postmyocardial infarction period, those with serious arrhythmias, and those with serious or worsening angina pectoris. Nasal/airway reactions -- Some 94% of users report moderate to severe nasal irritation in the first 2 days of use; 81% still reported nasal irritation after 3 weeks, although rated severity was mild to moderate. Nasal congestion and transient changes in sense of smell and taste also were reported. Nicotine nasal spray should not be used in persons with severe reactive airway disease. Dependency -- Nicotine nasal spray has a dependence potential intermediate between other nicotine-based therapies and cigarettes. About 15-20% of patients report using the active spray for longer periods than recommended (6-12 months), and 5% used the spray at a higher dose than recommended.
Dosage | A dose of nicotine nasal spray consists of one 0.5 mg delivery to each nostril (1 mg total). Initial dosing should be 1-2 doses per hour, increasing as needed for symptom relief. Minimum recommended treatment is 8 doses/day, with a maximum limit of 40 doses/day (5 doses/hr). Each bottle contains approximately 100 doses. Recommended duration of therapy is 3-6 months.
Availability | Nicotrol NS -- Prescription only.
Prescribing instructions | Dose delivery -- Patients should not sniff, swallow, or inhale through the nose while administering doses as this increases irritating effects. The spray is best delivered with the head tilted slightly back.
Cost/day ^a^ | $5.40 for 12 doses.

a Cost data is based on the retail price of the medication purchased at a national chain pharmacy located in Madison, WI April 2000.

### Nicotine Patch

Recommendation: The nicotine patch is an efficacious smoking cessation treatment that patients should be encouraged to use. (Strength of Evidence = A)

Twenty-seven studies met selection criteria and were included in the analysis comparing the nicotine patch to placebo. Results of this analysis are shown in Table 29. As can be seen from this analysis, the nicotine patch approximately doubles long-term abstinence rates over those produced by placebo interventions.

Table 29. Meta-analysis: Efficacy of and estimated abstinence rates for the nicotine patch (n = 27 studies)

Pharmacotherapy | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
Placebo | 28 | 1.0 | 10.0
Nicotine patch | 32 | 1.9 (1.7, 2.2) | 17.7 (16.0, 19.5)

The nicotine patch is available both as an over-the-counter medication and as a prescription medication. Suggestions regarding clinical use of the nicotine patch are provided in Table 37.

Table 37. Suggestions for the clinical use of the nicotine patch

| Clinical use for the nicotine patch (FDA approved)
Patient selection | Appropriate as a first-line pharmacotherapy for smoking cessation.
Precautions | Pregnancy -- Pregnant smokers should be encouraged to quit first without pharmacologic treatment. The nicotine patch should be used during pregnancy only if the increased likelihood of smoking abstinence, with its potential benefits, outweighs the risk of nicotine replacement and potential concomitant smoking. Similar factors should be considered in lactating women. (FDA Class C) Cardiovascular diseases -- NRT is not an independent risk factor for acute myocardial events. NRT should be used with caution among particular cardiovascular patient groups: those in the immediate (within 2 weeks) postmyocardial infarction period, those with serious arrhythmias, and those with serious or worsening angina pectoris. Skin reactions -- Up to 50% of patients using the nicotine patch will have a local skin reaction. Skin reactions are usually mild and self-limiting, but may worsen over the course of therapy. Local treatment with hydrocortisone cream (1%) or triamcinolone cream (0.5%) and rotating patch sites may ameliorate such local reactions. In less than 5% of patients, such reactions require the discontinuation of nicotine patch treatment. Other side effects -- insomnia.
Dosage | Treatment of 8 weeks or less has been shown to be as efficacious as longer treatment periods. 16-and 24-hour patches are of comparable efficacy. Clinicians should consider individualizing treatment based on specific patient characteristics such as previous experience with the patch, amount smoked, degree of addictiveness, etc. Finally, clinicians should consider starting treatment on a lower patch dose in patients smoking 10 or fewer cigarettes per day.
Availability | Nicoderm CQ, Nicotrol, generic -- OTC. Nicotine patches, generic (various doses) -- prescription.
Brand | Duration | Dosage
Nicoderm CQ | 4 weeks then 2 weeks then 2 weeks | 21 mg/24 hours 14 mg/24 hours 7 mg/24 hours
Nicotrol | 8 weeks | 15 mg/16 hours
Prescribing instructions | Location -- At the start of each day, the patient should place a new patch on a relatively hairless location, typically between the neck and waist. Activities -- No restrictions while using the patch. Time -- Patches should be applied as soon as the patient wakes on their quit day. With patients who experience sleep disruption, have the patient remove the 24-hour patch prior to bedtime or use the 16-hour patch.
Cost/day ^a^ | Brand name patches (Nicoderm CQ, Nicotrol) -- $4.00-$4.50. Generic patches recently became available and may be less expensive.

a Cost data is based on the retail price of the medication purchased at a national chain pharmacy located in Madison, WI April 2000.

## Recommendations Regarding Specific Pharmacotherapies: Second-Line Medications

Second-line medications are pharmacotherapies for which there is evidence of efficacy for treating tobacco dependence, but they have a more limited role than first-line medications because: (1) the FDA has not approved them for a tobacco dependence treatment indication; and (2) there are more concerns about potential side effects than exist with first-line medications. Second-line treatments should be considered for use on a case-by-case basis after first-line treatments have been used or considered.

The listing of the second-line medications is provided alphabetically. Meta-analyses did not contrast the relative efficacy of these medications.

### Clonidine

Recommendation: Clonidine is an efficacious smoking cessation treatment. It may be used under a physician's supervision as a second-line agent to treat tobacco dependence. (Strength of Evidence = A)

Five studies met selection criteria and were included in the analysis comparing clonidine to placebo. Results of this analysis are shown in Table 30. As can be seen from this analysis, the use of clonidine approximately doubles abstinence rates when compared to a placebo. These studies varied the clonidine dose from 0.1 to 0.75 mg/day. The drug was delivered either transdermally or orally. It should be noted that abrupt discontinuation of clonidine can result in symptoms such as nervousness, agitation, headache, and tremor, accompanied or followed by a rapid rise in blood pressure and elevated catecholamine levels.

Table 30. Meta-analysis: Efficacy of and estimated abstinence rates for clonidine (n = 5 studies)

Pharmacotherapy | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
Placebo | 6 | 1.0 | 13.9
Clonidine | 8 | 2.1 (1.4, 3.2) | 25.6 (17.7, 33.6)

Clonidine is used primarily as an antihypertensive medication and has not been approved by the FDA as a smoking cessation medication. Therefore, clinicians need to be aware of the specific warnings regarding this medication as well as its side-effect profile.

Additionally, a specific dosing regimen for the use of clonidine has not been established. Because of the warnings associated with clonidine discontinuation, the variability in dosages used to test this medication, and a lack of FDA approval, the guideline panel chose to recommend clonidine as a second-line agent. As such, clonidine should be considered for smoking cessation under a physician's direction with patients unable to use first-line medications because of contraindications or with patients who were unable to quit using first-line medications. Suggestions regarding clinical use of clonidine are provided in Table 38.

Table 38. Suggestions for the clinical use of clonidine

| Clinical use of clonidine (not FDA approved for smoking cessation)
Patient selection | Appropriate as a second-line pharmacotherapy for smoking cessation.
Precautions | Pregnancy -- Pregnant smokers should be encouraged to quit first without pharmacologic treatment. Clonidine should be used during pregnancy only if the increased likelihood of smoking abstinence, with its potential benefits, outweighs the risk of clonidine and potential concomitant smoking and first-line pharmacotherapies have not been successful. Similar factors should be considered in lactating women. (FDA Class C) Side effects -- Most commonly reported side effects include dry mouth (40%), drowsiness (33%), dizziness (16%), sedation (10%), and constipation (10%). As an antihypertensive medication, clonidine can be expected to lower blood pressure in most patients. Therefore, clinicians may need to monitor blood pressure when using this medication. Rebound hypertension -- Failure to gradually reduce the dose over a period of 2-4 days may result in a rapid increase in blood pressure, agitation, confusion, and/or tremor.
Dosage | Doses used in various clinical cessation trials have varied significantly, from 0.15-0.75 mg/day PO to 0.10-0.20 mg/day transdermal (TTS), without a clear dose-response relation to cessation. Initial dosing is typically 0.10 mg b.i.d. PO or 0.10 mg/day TTS, increasing by 0.10 mg/day per week if needed. The dose duration also varied across the clinical trials, ranging from 3-10 weeks.
Availability | Oral: Clonidine (generic), Catapres -- prescription only. Transdermal: Catapres -- prescription only.
Prescribing instructions | Initiate -- Initiate clonidine shortly before (up to 3 days), or on, the quit date. Location (TTS Only) -- At the start of each week, the patient should place a new patch on a relatively hairless location between the neck and waist. Activities -- Use of either form may produce sedation, a hazard while driving or operating machinery. Users should not discontinue clonidine therapy abruptly.
Cost/day ^a^ | Clonidine -- $0.24 for 0.2 mg. Catapres (transdermal) -- $3.50.

a Cost data is based on the retail price of the medication purchased at a national chain pharmacy located in Madison, WI April 2000.

### Nortriptyline

Recommendation: Nortriptyline is an efficacious smoking cessation treatment. It may be used under a physician's supervision as a second-line agent to treat tobacco dependence. (Strength of Evidence = B)

Two studies met selection criteria and were included in the analysis comparing nortriptyline to placebo. Results of this analysis are shown in Table 31. As can be seen from this analysis, the use of nortriptyline increases abstinence rates when compared to a placebo.

Table 31. Meta-analysis: Efficacy of and estimated abstinence rates for nortriptyline (n = 2 studies)

Pharmacotherapy | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
Placebo | 3 | 1.0 | 11.7
Nortriptyline | 3 | 3.2 (1.8, 5.7) | 30.1 (18.1, 41.6)

Nortriptyline is used primarily as an antidepressant and has not been evaluated or approved by the FDA as a smoking cessation medication. Clinicians need to be aware of the specific warnings regarding this medication as well as its side-effect profile. Because of the limited number of studies examining nortriptyline and the small sample sizes within those studies, the guideline panel determined that the recommendation warranted a strength of evidence equal to B. Because of this strength of evidence, the side-effect profile, and the lack of FDA approval for tobacco dependence treatment, nortriptyline is recommended as a second-line agent. As such, nortriptyline should be considered for smoking cessation under a physician's direction with patients unable to use first-line medications because of contraindications or with patients who were unable to quit using first-line medications. Suggestions regarding clinical use of nortriptyline are provided in Table 39.

Table 39. Suggestions for the clinical use of nortriptyline

| Clinical use of nortriptyline (not FDA approved for smoking cessation)
Patient selection | Appropriate as a second-line pharmacotherapy for smoking cessation.
Precautions | Pregnancy—Pregnant smokers should be encouraged to quit first without pharmacologic treatment. Nortriptyline should be used during pregnancy only if the increased likelihood of smoking abstinence, with its potential benefits, outweighs the risk of nortriptyline, potential concomitant smoking, and first-line pharmacotherapies have not been successful. Nortriptyline has been associated with limb reduction anomalies. Side effects -- Most commonly reported side effects include sedation, dry mouth (64-78%), blurred vision (16%), urinary retention, lightheadedness (49%), and shaky hands (23%). Cardiovascular effects -- Because of risk of arrhythmias, changes in contractility, and blood flow, use with extreme caution in patients with cardiovascular disease.
Dosage | Doses used in smoking cessation trials have initiated treatment at a dose of 25 mg/d, increasing gradually to a target dose of 75--100 mg/d. Duration of treatment used in smoking cessation trials has been approximately 12 weeks.
Availability | Nortriptyline HCl (generic) -- prescription only.
Prescribing instructions | Therapy is initiated 10--28 days before the quit date to allow nortriptyline to reach steady state at the target dose. Activities -- Use may produce sedation, a hazard while driving or operating machinery. Overdose may produce marked cardiotoxic effects. Risk of overdose should be considered carefully in using nortriptyline.
Cost/day ^a^ | $0.74 for 75 mg.

a Cost data is based on the retail price of the medication purchased at a national chain pharmacy located in Madison, WI April 2000.

### Combination Nicotine Replacement Therapy

Recommendation: Combining the nicotine patch with a self-administered form of nicotine replacement therapy (either the nicotine gum or nicotine nasal spray) is more efficacious than a single form of nicotine replacement, and patients should be encouraged to use such combined treatments if they are unable to quit using a single type of first-line pharmacotherapy. (Strength of Evidence = B)

Three studies met selection criteria for the combination nicotine replacement therapy (NRT) meta-analysis. This analysis was intended to address the hypothesis that combination pharmacotherapy is more effective than monotherapy (the use of a single pharmacotherapy) if the combination therapy comprises two different types of pharmacotherapy. Specifically, the hypothesis holds that one type of pharmacotherapy should involve passive dosing that produces relatively steady levels of drug in the body, while the second type of pharmacotherapy should permit ad libitum dosing that allows the user to adjust dosing on an acute basis.^111,^ ^112^ All three studies used the nicotine patch (15 mg) as one of the medications; in two studies the patch was supplemented with nicotine gum (2 mg),^113,^ ^114^ and in the remaining study the patch was supplemented with nicotine nasal spray.^115^ Comparison subjects receiving monotherapy were given the nicotine patch in two of these studies and nicotine gum in the third.

The results of the combination NRT meta-analysis are displayed in Table 32. The results show that the combination NRT treatment produced higher long-term abstinence rates than did NRT monotherapy. The recommendation to use combination NRT carries a strength of evidence rating of B. This is because the small number of studies in this analysis contained heterogeneous combination treatments as well as heterogeneous comparison conditions. It is important to note that the FDA has not approved a combination NRT strategy for treatment of smoking cessation. Because there is relatively little safety data on the conjoint use of NRTs, and because combination NRT could increase the risk of nicotine overdose, the panel recommends that this treatment strategy be used only with those patients unable to quit using a single type of pharmacotherapy. Combination NRT also is more expensive than is the use of a single NRT. This extra cost should be considered in making recommendations about NRT use.

Table 32. Meta-analysis: Efficacy of and estimated abstinence rates for combination NRT (n = 3 studies)

Factor | Number of arms | Odds ratio | Estimated abstinence rate (95% C.I.)
One NRT | 3 | 1.0 | 17.4
Two NRTs | 3 | 1.9 (1.3, 2.6) | 28.6 (21.7, 35.4)

Two studies have examined the impact of the combination of the nicotine patch plus nicotine gum on the suppression of the nicotine withdrawal syndrome.^111,^ ^116^ These studies show that combination NRT is more effective than a single NRT.

It is unknown whether the superiority of combination therapy is due to the use of two types of delivery systems, or instead due to the fact that two delivery systems tend to produce higher blood nicotine levels than does the use of a single type of NRT. However, there is only modest evidence that using two forms of passive pharmacotherapies or increasing the dose of a single NRT increases long-term abstinence rates.^117,^ ^118,^ ^119,^ ^120^ This suggests that the increment in success produced by combination NRTs may depend on the use of two distinct delivery systems: one passive and one ad libitum. This conclusion must remain tentative until more research is conducted on this topic. Finally, there is not yet sufficient data to determine whether combination NRTs are particularly efficacious with subpopulations of smokers (e.g., those high in nicotine dependence).

## Pharmacotherapies Not Recommended by the Guideline Panel

### Antidepressants Other Than Bupropion SR and Nortriptyline

Smoking is significantly more prevalent among individuals with a history of depression, and these individuals have more difficulty quitting smoking than do smokers without a history of depression.^121,^ ^122,^ ^123^ One antidepressant, bupropion SR, has been documented as effective for smoking cessation and approved by the FDA for this use (see above). Nortriptyline also appears to be effective (see above), although the FDA has not approved this medication for treatment of tobacco dependence. Trials have investigated the use of other antidepressants for smoking cessation, including other tricyclics and selective serotonin reuptake inhibitors (SSRIs), but no published articles met selection criteria for review. Because of a paucity of data, the panel drew no conclusions about antidepressant therapy for smoking cessation except to recommend bupropion SR as a first-line agent and nortriptyline as a second-line agent.

### Anxiolytics/Benzodiazepines/Beta-Blockers

A few trials have evaluated anxiolytics as a treatment for smoking cessation. Individual trials of propranolol^124^ (a beta-blocker) and diazepam^125^ (an anxiolytic) did not reveal a beneficial effect for these drugs compared with control interventions. Of the two studies assessing the anxiolytic buspirone that met inclusion criteria, only one revealed evidence of efficacy relative to placebo.^126,^ ^127^ Because of a lack of data, no meta-analyses were conducted, and no conclusions were drawn regarding the efficacy of anxiolytics in smoking cessation.

### Silver Acetate

The two randomized clinical trials^128,^ ^129^ of silver acetate that met selection criteria revealed no beneficial effects for smoking cessation; therefore, the use of silver acetate as either a primary or an adjunctive treatment for smoking cessation was not supported.

### Mecamylamine

Two studies meeting selection criteria evaluated the efficacy of mecamylamine for smoking cessation. In the single study that compared mecamylamine alone to placebo, no efficacy was noted.^130^ In both studies, one combination of mecamylamine plus the nicotine patch was compared to placebo; in only one of these studies was the difference significant.^131^ Because of these findings, the panel drew no conclusions regarding mecamylamine as a sole medication.

## Pharmacotherapy for Treating Tobacco Dependence: Issues Relevant to Use

### Overcoming Clinician Reluctance to Use Pharmacotherapy

Some clinicians are reluctant to recommend and prescribe pharmacotherapy for their patients who smoke. Several reasons have been cited for this reluctance, including clinician beliefs that are prevalent, but not supported by evidence. Examples of such beliefs are: smoking is a lifestyle choice and not a true dependence disorder; pharmacotherapy should be reserved for heavily dependent smokers, or used only in conjunction with an intensive cessation treatment; and smokers will be most successful if they first try to quit on their own.

Clinical and epidemiological data strongly counter these beliefs. A variety of findings show that tobacco dependence meets all accepted criteria for a drug dependence disorder. In most users, tobacco use produces tolerance, a well-characterized withdrawal syndrome, and an inability to control future use.^25^ Thus, tobacco dependence warrants medical treatment just as do other drug dependence disorders and other chronic diseases.

The panel concluded that, in the vast majority of cases, it is inappropriate to reserve pharmacotherapy until patients have tried to quit on their own. Although many smokers have quit on their own, the vast majority of unaided quit attempts, between 90-95 percent, end in failure.^2,^ ^65^ By using the pharmacotherapies found to be effective in this guideline, clinicians can double or triple their patients' chances of abstinence. Pharmacotherapies recommended in this guideline have been used effectively with psychosocial treatments that have varied greatly in intensity. When intensity of adjuvant treatments has been examined, data reveal that the pharmacotherapies are effective at low as well as high levels of psychosocial treatment intensity.^132,^ ^133^ Therefore, clinicians should recommend effective psychosocial treatments such as counseling, in addition to pharmacotherapy, to all patients for whom it is appropriate. Finally, pharmacotherapies are effective for a broad range of smokers, not just "hardcore" smokers.

### Extended Use of Pharmacotherapy

For some patients, it may be appropriate to continue pharmacotherapeutic treatment (bupropion SR or NRT) for periods longer than usually recommended. The Lung Health Study, which studied almost 4,000 smokers with early evidence COPD, reported that of the sustained quitters, 38 percent of the women and 30 percent of the men were still using nicotine gum at 12 months.^134^ Other studies also have found that, among patients given free access to nicotine gum, 15-20 percent of successful abstainers continue to use the gum for a year or longer.^135,^ ^136^ Although weaning should be encouraged for all smoking cessation pharmacotherapies, continued use of such medication is clearly preferable to a return to smoking with respect to health consequences. This is because, unlike smoking, these medications do not (a) contain non-nicotine toxic substances (e.g., "tar," carbon monoxide); (b) produce dramatic surges in blood nicotine levels; and/or (c) produce strong dependence.^137^

## Recommending Specific Pharmacotherapy for Specific Patient Subgroups

There are five FDA-approved medications for treating tobacco dependence. Clinicians are interested in which medications to use with which patients. Unfortunately, this guideline provides little guidance on this topic because of a lack of relevant research. Some studies have directly compared the efficacies of FDA-approved pharmacotherapies;^118^ however, there are too few studies to yield definitive conclusions.

More research is needed before evidence-based pharmacotherapy algorithms can be formulated; however, several factors may guide the clinician in choosing medications for specific patient subpopulations. For example, highly dependent smokers who use nicotine gum should be urged to use 4 mg, as opposed to 2 mg, gum.^109,^ ^110^ Also, bupropion SR and nortriptyline have been demonstrated to be efficacious in patients trying to quit who have a history of depression.^138,^ ^139^ Additionally, for patients concerned about weight gain some pharmacotherapies (e.g., bupropion SR, NRT, in particular nicotine gum) have been shown to delay but not prevent weight gain during their use. Moreover, research suggests that some treatments (e.g., NRTs) are less efficacious in women than in men.^140,^ ^141^ Finally, patient preferences and patient expectations regarding outcome also are important in guiding the choice of a specific pharmacotherapy.^142^ A series of clinical recommendations for pharmacotherapy selection is shown in Table 4 in Chapter 3. For a description of some of the issues related to the use of pharmacotherapy with pregnant women, please refer to the Pregnancy section in Chapter 7.

Currently, there is insufficient evidence to suggest that the use of tobacco dependence pharmacotherapies increases long-term abstinence rates among users of smokeless tobacco. Specifically, studies conducted with nicotine gum and the nicotine patch have shown that these two medications have not increased abstinence rates in this population.^143^

### Use of Nicotine Replacement Therapy in Cardiovascular Patients

Soon after the nicotine patch was released, the media reported a possible link between the use of this medication and cardiovascular risk. This question has been systematically studied since that time. Separate analyses have now documented the lack of an association between the nicotine patch and acute cardiovascular events^144,^ ^145,^ ^146^ even in patients who continued to smoke intermittently while on the nicotine patch.^147^ Because of inaccurate media coverage in the past, it may be important to inform patients who are reluctant to use NRTs that there is no evidence of increased cardiovascular risk with these medications. Note that package inserts recommend caution with acute cardiovascular diseases (see Tables 33-37).

### Future Research

The following pharmacotherapeutic topics require additional research:

- The effectiveness of a nicotine sublingual tablet as a tobacco dependence medication.
- The effectiveness of buspirone as a tobacco dependence medication.
- The effectiveness of mecamylamine as a tobacco dependence medication, both used alone and in combination with other medications.
- The use of sustained or long-term pharmacotherapy for treating tobacco dependence.
- The use of other antidepressants or anxiolytics as tobacco dependence medications.
- The relative efficacy and safety of the five FDA-approved pharmacotherapies both, in general, and for specific subpopulations (e.g., women, adolescents, smokeless users, depressed patient, post-myocardial infarction patients).
- The use of combined tobacco dependence pharmacotherapies in general and for specific subpopulations (e.g., highly dependent smokers).
- The efficacy of combining active and passive NRTs versus combining two active or two passive NRTs.
- When clonidine and nortriptyline should be used in lieu of or in combination with other tobacco dependence pharmacotherapies.
- The optimal combination of counseling and pharmacotherapy intensities (see Tables 38 and 39).

### Over-the-Counter Pharmacotherapeutic Interventions

Recommendation: Over-the-counter nicotine patch therapy is more efficacious than placebo and its use should be encouraged. (Strength of evidence =B)

There were three placebo-controlled studies with six arms that met selection criteria for the analysis of pharmacotherapeutic interventions in over-the-counter (OTC) settings. These three studies specifically examined the effect of patch versus placebo. The only adjuvant treatments in these studies were a self-help manual, instructions contained in the package, or written directions for using the patch. As shown in Table 40, the use of the nicotine patch in OTC settings nearly doubles abstinence rates when compared against a placebo. There were too few studies done in the OTC setting to permit meta-analysis of the OTC effect of any other pharmacotherapy.

Table 40. Meta-analysis: Efficacy of and estimated abstinence rates for over-the-counter nicotine patch therapy (n = 3 studies)

OTC therapy | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
Placebo | 3 | 1.0 | 6.7
Over-the-counter nicotine patch therapy | 3 | 1.8 (1.2, 2.8) | 11.8 (7.5, 16.0)

The FDA has approved nicotine gum and the nicotine patch for OTC use. These products are identical to the patches and gum previously available only via prescription. Although the OTC status of these medications has increased their availability and use, this does not reduce the clinician's responsibility to intervene with smokers or insurers/managed care organizations to cover the costs of such treatment. Moreover, OTC availability may enhance the capacity of nonphysician clinicians to intervene comprehensively when treating tobacco dependence.

All clinicians have specific responsibilities regarding these products, such as encouraging their use when appropriate, providing counseling and followup, encouraging total abstinence, and offering instruction on appropriate use. Additionally, patients should be urged to read the package insert and consult with their pharmacist. Finally, the clinician may advise patients regarding the selection and use of an OTC product versus a non-OTC product such as bupropion SR or a prescription nicotine replacement treatment (nasal spray or inhaler). Clinicians also may provide or recommend counseling for patients quitting with an OTC product. It should be noted that a single recent study not included within the meta-analysis reported low abstinence rates with OTC patch use.^148^

### Future Research

Important topics for future research are:

- The efficacy of nicotine patch and nicotine gum when access is OTC.
- The extent to which individuals use pharmacotherapies optimally when access is OTC.
- The extent to which the efficacy of OTC pharmacotherapy is enhanced by adjuvant treatments (e.g., pharmacist counseling, telephone counseling, computer self-help resources, clinician interventions).
- The extent to which OTC status increases or reduces the use of pharmacotherapies by poor or minority populations.