# Systems Interventions: Relevance to Health Care Administrators, Insurers, and Purchasers

## Background

Traditionally, efforts to increase tobacco intervention in the health care setting have targeted the individual clinician. Such a restricted focus is no longer appropriate. Two considerations argue for expanding the scope of tobacco intervention efforts. First, efforts directed at the individual clinician have yielded disappointing results. For instance, national data suggest that, in a given visit with a clinician, more than one-third of smokers are not advised and assisted with cessation.^11,^ ^14,^ ^41^ Second, an increasing number of Americans today receive their health care in managed care settings. As a consequence, agents such as health system administrators, insurers, and health care purchasers now play a significant role in the health care of most Americans. For example, managed care organizations and other insurers influence medical care through restrictive formularies, performance feedback to clinicians, and marketing approaches that prompt patient demand for particular services.

The influence of health care system administrators, insurers, and purchasers could, in theory, be used to encourage and support the consistent and effective identification and treatment of tobacco users. These agents could craft and implement supportive systems, policies, and environmental prompts that render tobacco use treatment an integral part of health care. Indeed, research clearly shows that systems-level change can reduce smoking prevalence among enrollees of managed health care plans.^66^

Unfortunately, as a society we have not capitalized on the opportunity to use today's health care organizations, insurers, and purchasers to combat tobacco use. For example, treatments for tobacco use (both pharmacotherapy and counseling) are not consistently provided as paid services for subscribers of health insurance packages.^67,^ ^68^ A recent survey found that only 22 States provided Medicaid coverage for tobacco dependence treatment.^69^ Another survey demonstrated that only 39 percent of managed care organizations had partially implemented the recommendations within the original guideline, and only 9 percent had fully implemented the recommendations.^70^ This lack of coverage is puzzling given that studies have shown that physician advice to quit is at least as cost-effective as several other preventive medical practices, including the treatment of mild or moderate hypertension or high cholesterol.^71,^ ^72^ These and other findings resulted in the addition of a new objective to the national health promotion and disease prevention objectives for the year 2000 (Healthy People 2000):

- Increase to 100 percent the proportion of health plans that offer treatment of nicotine addiction (e.g., tobacco use cessation counseling by health care providers, tobacco use cessation classes, prescriptions for nicotine replacement therapies, and/or other cessation services).^73^
- This objective has been modified in Healthy People 2010 to state:
- Increase insurance coverage of evidence-based treatment for nicotine dependency to 100 percent.^74^

In sum, without supportive systems, policies, and environmental prompts, the individual clinician will likely not assess and treat tobacco use consistently. Therefore, just as clinicians must assume responsibility to treat their patients for tobacco use, so must health care administrators, insurers, and purchasers assume responsibility to craft policies, provide resources, and display leadership that results in consistent and effective tobacco use treatment.

## Cost-Effectiveness of Smoking Cessation Interventions

Smoking cessation treatments are not only clinically effective, but they are economically defensible as well. It is vital that all three audiences targeted in this guideline recognize that smoking cessation treatments ranging from clinician advice to pharmacotherapy to specialist-delivered intensive programs are cost-effective in relation to other medical interventions.^64^ Cost-effectiveness analyses have shown that smoking cessation treatments compare quite favorably with routine medical interventions such as the treatment of hypertension and hypercholesterolemia, and with other preventive interventions such as periodic mammography.^71,^ ^75,^ ^76,^ ^77^ In fact, smoking cessation treatment has been referred to as the "gold standard" of preventive interventions.^78^ Smoking cessation treatment remains highly cost-effective, even though a single application of any effective treatment for tobacco dependence may produce sustained abstinence in only a minority of smokers.

The cost-effectiveness of guideline recommendations for smoking cessation is addressed in detail in Chapter 8.

## Recommendations for Health Care Administrators, Insurers, and Purchasers

Health care delivery administrators, insurers, and purchasers can promote the treatment of tobacco dependence through a systems approach. Purchasers (often corporations, companies, or other consortia that purchase health care benefits for a group of individuals) should make tobacco assessment and treatment a contractual obligation of the health care insurers and/or providers that sell services to them. In addition to improving the health of their employees or subscribers, mandating coverage for tobacco dependence treatment will result in lower rates of absenteeism^79^ and lower utilization of health care resources.^80^ Health care administrators and insurers must provide clinicians with assistance to ensure that institutional changes promoting tobacco dependence treatment are implemented universally and systematically. A number of institutional policies would facilitate these interventions such as:

- Implementing a tobacco-user identification system in every clinic (Systems Strategy 1).
- Providing education, resources, and feedback to promote provider intervention (Systems Strategy 2).
- Dedicating staff to provide tobacco dependence treatment and assessing the delivery of this treatment in staff performance evaluations (Systems Strategy 3).
- Promoting hospital policies that support and provide tobacco dependence services (Systems Strategy 4).
- Including tobacco dependence treatments (both counseling and pharmacotherapy) identified as effective in this guideline, as paid or covered services for all subscribers or members of health insurance packages (Systems Strategy 5).
- Reimbursing clinicians and specialists for delivery of effective tobacco dependence treatments and including these interventions among the defined duties of the clinicians (Systems Strategy 6).

These strategies are based on the evidence described in Chapters 6, 7, and 8, as well as on panel opinion.

## Strategies for Health Care Administrators, Insurers and Purchasers

Systems Strategy 1. Implement a tobacco-user identification system in every clinic

Action | Strategies for implementation
Implement an office-wide system that ensures that, for EVERY patient at EVERY clinic visit, tobacco-use status is queried and documented. | Office system change: Expanding the Vital Signs to include tobacco use or implement an alternative universal identification system. Responsible staff: Nurse, medical assistant, receptionist, or other individual already responsible for measuring the vital signs. These staff must be instructed regarding the importance of this activity and serve as non-smoking role models. Frequency of utilization: Every visit for every patient regardless of the reason for the visit. ^a^ System implementation steps: Prepare progress notepaper or computer records to include tobacco use along with the traditional vital signs for every patient visit. A vital sign stamp also can be used. Alternatives to the vital sign stamp are to place tobacco-use status stickers on all patient charts or to indicate smoking status using computer reminder systems. Vital Signs Blood Pressure: ___________ Pulse: _____ Weight: ______ Temperature: ______________ Respiratory Rate: _________ Tobacco Use: Current Former Never (circle one)

aRepeated assessment is not necessary in the case of the adult who has never used tobacco or not used tobacco for many years, and for whom this information is clearly documented in the medical record.

Systems Strategy 2. Provide education, resources, and feedback to promote provider intervention

Action | Strategies for implementation
Health care systems should ensure that clinicians have sufficient training to treat tobacco dependence, clinicians and patients have cessation resources, and clinicians are given feedback about their tobacco dependence treatment practices. | Educate—On a regular basis, offer lectures/seminars/ in-services with CME and/or other credit for tobacco dependence treatment. Provide resources -- Have patient self-help materials, as well as bupropion SR and nicotine replacement "starter kits," readily available in every examination room. Report -- Include the provision of tobacco dependence treatment on "report cards" for managed care organizations and other insurers (e.g., NCQA HEDIS). Provide feedback -- Drawing on data from chart audits, electronic medical records, and computerized patient databases, evaluate the degree to which clinicians are identifying, documenting, and treating patients who use tobacco, and provide feedback to clinicians about their performance.

Systems Strategy 3. Dedicate staff to provide tobacco dependence treatment and assess the delivery of this treatment in staff performance evaluations

Action | Strategies for implementation
Clinical sites should communicate to all staff the importance of intervening with tobacco users and should designate a staff person (e.g., nurse, medical assistant, or other clinician) to coordinate tobacco dependence treatments. Nonphysician personnel may serve as effective, but lower cost, providers of tobacco dependence interventions. | Designate a tobacco dependence treatment coordinator for every clinical site. Delineate the responsibilities of the tobacco dependence treatment coordinator, including instructing patients on the effective use of treatments (e.g., pharmacotherapy, telephone calls to and from prospective quitters, and scheduled followup visits, especially in the immediate post-quit period). Communicate to each staff member (e.g., nurse, physician, medical assistant, pharmacist, or other clinician) his or her responsibilities in the delivery of tobacco dependence services. Incorporate a discussion of these staff responsibilities into training of new and temporary staff.

Systems Strategy 4. Promote hospital policies that support and provide inpatient tobacco dependence services

Action | Strategies for implementation
Provide tobacco dependence treatment to all tobacco users admitted to a hospital. | Implement a system to identify and document the tobacco-use status of all hospitalized patients. Identify a clinician(s) to deliver tobacco dependence in-patient consultation services for every hospital. Offer tobacco dependence treatment to all hospitalized patients who use tobacco. Reimburse providers for tobacco dependence in-patient consultation services. Expand hospital formularies to include FDA-approved tobacco dependence pharmacotherapies. Ensure compliance with JCAHO regulations mandating that all sections of the hospital be entirely smoke-free. Educate hospital staff that first-line medications may be used to reduce nicotine withdrawal symptoms, even if the patient is not intending to quit.

Systems Strategy 5. Include tobacco dependence treatments (both counseling and pharmacotherapy) identified as effective in this guideline, as paid or covered services for all subscribers or members of health insurance packages

Action | Strategies for implementation
Provide all insurance subscribers, including MCO members, with coverage for effective tobacco dependence treatments, including pharmacotherapy and counseling. | Cover—Include effective tobacco dependence treatments (both counseling and pharmacotherapy) as part of the basic benefits package for all health insurance packages. Educate -- Inform subscribers, including MCO members, of the availability of covered tobacco dependence treatments (both counseling and pharmacotherapy) and encourage patients to use these services.

Systems Strategy 6. Reimburse clinicians and specialists for delivery of effective tobacco dependence treatments and include these interventions among the defined duties of clinicians

Action | Strategies for implementation
Reimburse fee-for-service clinicians and specialists for delivery of effective tobacco dependence treatments; include tobacco dependence treatments in the defined duties of salaried clinicians and those working in capitated environments. | Include tobacco dependence treatment as a reimbursable activity for fee-for-service providers. Inform fee-for-service clinicians and specialists that they will be reimbursed for using effective tobacco dependence treatments. Include tobacco dependence intervention in the job descriptions and performance evaluations of salaried clinicians and specialists.