# Intensive Clinical Interventions

## Background

Intensive tobacco dependence treatment can be provided by any suitably trained clinician who has the resources available to give intensive interventions. Based on the evidence in Chapter 6, it has been shown that more intensive tobacco dependence treatment is more effective than brief treatment. Also, it should be noted that intensive interventions are appropriate for any tobacco user willing to participate in them. There is no evidence that the efficacy or cost-effectiveness of intensive interventions is limited to a subpopulation of tobacco users (e.g., heavily dependent smokers).^64^

In many cases, intensive tobacco dependence interventions are provided by clinicians who specialize in the treatment of tobacco dependence. Such specialists are not defined by their professional affiliation or by the field in which they trained. Rather, specialists view tobacco dependence treatment as a primary professional role. Specialists possess the skills, knowledge, and training to provide efficacious interventions across a range of intensities, and are often affiliated with programs offering intensive treatment interventions or services (programs with staff dedicated to tobacco interventions, where treatment involves multiple counseling sessions, and so on). In addition to offering intensive treatments, specialists often conduct research on tobacco dependence and its treatment.

As noted above, there is substantial evidence that intensive interventions produce higher success rates than do less intensive interventions (as indicated by several findings of this guideline). In addition, the tobacco dependence interventions offered by specialists represent an important treatment resource for patients who do not receive tobacco dependence treatment from their primary care clinician.

Although the specialist contributes greatly to tobacco treatment efforts, constraints limit the impact of the specialist's service delivery activities. For example, only a minority of smokers participate in the intensive programs typically offered by specialists.^51,^ ^65^ This suggests that, in the future, the specialist may contribute to tobacco treatment efforts through activities such as the following:

- Serving as a resource to nonspecialists who offer tobacco dependence services as part of general health care delivery. This might include training nonspecialists in counseling strategies, providing consultation on difficult cases and for inpatients, and providing specialized assessment services.
- Developing and evaluating changes in office/clinic procedures that increase the rates at which tobacco users are identified and treated.
- Conducting evaluation research to determine the effectiveness of ongoing tobacco dependence treatment activities in relevant institutional settings.
- Developing and evaluating innovative treatment strategies that may increase the effectiveness and utilization of tobacco dependence treatments.

## Strategies for Intensive Tobacco Dependence Intervention

Table 5 highlights guideline findings based on analyses found in Chapter 6, as well as on panel opinion, that seem particularly relevant to the implementation of intensive treatment programs. The findings from Table 5 lead to the development of an intensive treatment strategy (see Intensive Strategy. Components of an intensive intervention). Of course, implementation of this strategy depends on factors such as resource availability and time constraints.

Table 5. Findings relevant to intensive interventions

- There is a strong dose-response relation between counseling intensity and cessation success. In general, the more intense the treatment intervention, the greater the rate of smoking cessation. Treatments may be made more intense by increasing (a) the length of individual treatment sessions and (b) the number of treatment sessions.
- Many different types of providers (physicians, nurses, dentists, psychologists, pharmacists, etc.) are effective in increasing rates of tobacco cessation, and involving multiple types of providers may enhance abstinence rates.
- Proactive telephone calls and individual and group counseling are effective tobacco cessation formats.
- Particular types of counseling and behavioral therapies are especially effective. Practical counseling (problemsolving/skills-training approaches), and the provision of intra-treatment and extra-treatment social support are associated with significant increases in abstinence rates, as are aversive smoking techniques (e.g., rapid smoking).
- Pharmacotherapies such as bupropion SR or nicotine replacement therapies consistently increase abstinence rates. Therefore, their use should be encouraged for all quitters, but special consideration is required with some populations (e.g., pregnant smokers, adolescents).
- Tobacco dependence treatments are effective across diverse populations (e.g., populations varying on gender, age, and ethnicity).

Intensive Strategy Components of an intensive intervention

Assessment | Assessments should ensure that tobacco users are willing to make a quit attempt using an intensive treatment program. Other assessments can provide information useful in counseling (e.g., stress level, presence of comorbidity; see Chapter 6A, Specialized Assessment).
Program clinicians | Multiple types of clinicians are effective and should be used. One counseling strategy would be to have a medical/health care clinician deliver messages about health risks and benefits and deliver pharmacotherapy, and nonmedical clinicians deliver additional psychosocial or behavioral interventions.
Program intensity | Because of evidence of a strong dose-response relation, the intensity of the program should be: Session length—longer than 10 minutes. Number of sessions -- 4 or more sessions. Total contact time -- longer than 30 minutes.
Program format | Either individual or group counseling may be used. Proactive telephone counseling also is effective. Use of adjuvant self-help material is optional. Followup assessment intervention procedures should be used (see Chapter 6B).
Type of counseling and behavioral therapies | Counseling and behavioral therapies should involve practical counseling (problemsolving/skills-training) (see Table 21) and intra-treatment (see Table 22) and extra-treatment social support (see Table 23).
Pharmacotherapy | Every smoker should be encouraged to use pharmacotherapies endorsed in this guideline, except in the presence of special circumstances. Special consideration should be given before using pharmacotherapy with selected populations (e.g., pregnancy, adolescents) (see Table 4 for clinical guidelines and Tables 33-39 for specific instructions and precautions). The clinician should explain how these medications increase smoking cessation success and reduce withdrawal symptoms. The first-line pharmacotherapy agents include: bupropion SR, nicotine gum, nicotine inhaler, nicotine nasal spray, and the nicotine patch.
Population | Intensive intervention programs may be used with all tobacco users willing to participate in such efforts.