# Brief Clinical Interventions

## Background

This section of the guideline presents specific strategies to guide clinicians providing brief interventions. These brief interventions can be provided by any clinician but are most relevant to primary care clinicians (physicians, nurses, dentists, hygienists, respiratory therapists, pharmacists, etc.) who see a wide variety of patients, and who are bound by time constraints. These strategies are based on the evidence described in Chapters 6, 7, and 8, as well as on panel opinion. Guideline analysis suggests that a wide variety of clinicians can implement these brief strategies effectively. The goals of these strategies are clear: to change clinical culture and practice patterns to ensure that every patient who uses tobacco is identified and offered treatment. The strategies underscore a central theme: it is essential to provide at least a brief intervention to all tobacco users at each clinical visit. Several observations are relevant to this theme. First, institutional changes in clinical practice are necessary to ensure that all patients who use tobacco are identified for intervention (see Chapter 5, Systems Interventions: Relevance to Health Care Administrators, Insurers, and Purchasers). Second, the compelling time limits on primary care physicians in the United States today^49^ (median visit = 12 to 16 minutes)^50^ often require brief interventions, although more intensive interventions would produce greater success. Third, although many smokers are reluctant to seek intensive cessation programs,^51^ they nevertheless can receive a brief intervention every time they visit a clinician.^22^

This Chapter is divided into three sections to guide brief clinician interventions with three types of patients: (A) current tobacco users now willing to make a quit attempt; (B) current tobacco users unwilling at this time to make a quit attempt; and (C) former tobacco users who have recently quit. Adults who have never used tobacco or who have been abstinent for an extended period do not require intervention. The clinician may congratulate them on their status and encourage them to maintain their tobacco-free lifestyle.

## A. For the Patient Willing To Quit

Given that so many tobacco users visit a primary care clinician each year, it is important that these clinicians be prepared to intervene with tobacco users who are willing to quit. The five major steps (the "5 A's") to intervention in the primary care setting are listed in Table 3. It is important for the clinician to ask the patient if he or she uses tobacco (Brief Strategy A1), advise him or her to quit (Brief Strategy A2), assess willingness to make a quit attempt (Brief Strategy A3), assist him or her in making a quit attempt (Brief Strategy A4), and arrange for followup contacts to prevent relapse (Brief Strategy A5). The strategies are designed to be brief, requiring 3 minutes or less of direct clinician time. Office systems that institutionalize tobacco use assessment and intervention will greatly foster the adoption of these strategies (see Chapter 5). Finally, these strategies are consistent with those produced by the NCI^13,^ ^52^ and the American Medical Association,^27^ as well as others,^26,^ ^53,^ ^54^

Table 3. The "5 A's" for brief intervention

Ask about tobacco use. | Identify and document tobacco use status for every patient at every visit. (Brief Strategy A1)
Advise to quit. | In a clear, strong and personalized manner urge every tobacco user to quit. (Brief Strategy A2)
Assess willingness to make a quit attempt. | Is the tobacco user willing to make a quit attempt at this time? (Brief Strategy A3)
Assist in quit attempt. | For the patient willing to make a quit attempt, use counseling and pharmacotherapy to help him or her quit. (Brief Strategy A4)
Arrange followup. | Schedule followup contact, preferably within the first week after the quit date. (Brief Strategy A5)

In addition to counseling, all smokers making a quit attempt should receive pharmacotherapy, except in the presence of special circumstances. See Table 4 for guidelines for prescribing pharmacotherapy for smoking cessation.

Table 4. Clinical guidelines for prescribing pharmacotherapy for smoking cessation

Who should receive pharmacotherapy for smoking cessation? | All smokers trying to quit, except in the presence of special circumstances. Special consideration should be given before using pharmacotherapy with selected populations: those with medical contraindications, those smoking fewer than 10 cigarettes/day, pregnant/breastfeeding women, and adolescent smokers.
What are the first-line pharmacotherapies recommended in this guideline? | All five of the FDA-approved pharmacotherapies for smoking cessation are recommended, including bupropion SR, nicotine gum, nicotine inhaler, nicotine nasal spray, and the nicotine patch.
What factors should a clinician consider when choosing among the five first-line pharmacotherapies? | Because of the lack of sufficient data to rank-order these five medications, choice of a specific first-line pharmacotherapy must be guided by factors such as clinician familiarity with the medications, contraindications for selected patients, patient preference, previous patient experience with a specific pharmacotherapy (positive or negative), and patient characteristics (e.g., history of depression, concerns about weight gain).
Are pharmacotherapeutic treatments appropriate for lighter smokers (e.g., 10-15 cigarettes/day)? | If pharmacotherapy is used with lighter smokers, clinicians should consider reducing the dose of first-line NRT pharmacotherapies. No adjustments are necessary when using bupropion SR.
What second-line pharmacotherapies are recommended in this guideline? | Clonidine and nortriptyline.
When should second-line agents be used for treating tobacco dependence? | Consider prescribing second-line agents for patients unable to use first-line medications because of contraindications or for patients for whom first-line medications are not helpful. Monitor patients for the known side effects of second-line agents.
Which pharmacotherapies should be considered with patients particularly concerned about weight gain? | Bupropion SR and nicotine replacement therapies, in particular nicotine gum, have been shown to delay, but not prevent, weight gain.
Are there pharmacotherapies that should be especially considered in patients with a history of depression? | Bupropion SR and nortriptyline appear to be effective with this population.
Should nicotine replacement therapies be avoided in patients with a history of cardiovascular disease? | No. The nicotine patch in particular is safe and has been shown not to cause adverse cardiovascular effects.
May tobacco dependence pharmacotherapies be used long-term (e.g., 6 months or more)? | Yes. This approach may be helpful with smokers who report persistent withdrawal symptoms during the course of pharmacotherapy or who desire long-term therapy. A minority of individuals who successfully quit smoking use ad libitum NRT medications (gum, nasal spray, inhaler) long-term. The use of these medications long-term does not present a known health risk. Additionally, the FDA has approved the use of bupropion SR for a long-term maintenance indication.
May pharmacotherapies ever be combined? | Yes. There is evidence that combining the nicotine patch with either nicotine gum or nicotine nasal spray increases long-term abstinence rates over those produced by a single form of NRT.

### Brief Strategies: Helping the Patient Willing To Quit

Brief Strategy A1. Ask -- systematically identify all tobacco users at every visit

Action | Strategies for implementation
Implement an office-wide system that ensures that, for EVERY patient at EVERY clinic visit, tobacco-use status is queried and documented. ^a^ | Expand the vital signs to include tobacco use or use an alternative universal identification system. ^b^ Vital Signs Blood Pressure: ___________ Pulse: _____ Weight: ______ Temperature: ______________ Respiratory Rate: _________ Tobacco Use: Current Former Never (circle one)

Brief Strategy A2. Advise -- strongly urge all tobacco users to quit

Action | Strategies for implementation
In a clear, strong, and personalized manner, urge every tobacco user to quit. | Advice should be:; - Clear -- "I think it is important for you to quit smoking now and I can help you." "Cutting down while you are ill is not enough."; - Strong -- "As your clinician, I need you to know that quitting smoking is the most important thing you can do to protect your health now and in the future. The clinic staff and I will help you."; - Personalized -- Tie tobacco use to current health/illness, and/or its social and economic costs, motivation level/readiness to quit, and/or the impact of tobaccmo use on children and others in the household.

Brief Strategy A3. Assess -- determine willingness to make a quit attempt

Action | Strategies for implementation
Ask every tobacco user if he or she is willing to make a quit attempt at this time (e.g., within the next 30 days). | Assess patient's willingness to quit:; - If the patient is willing to make a quit attempt at this time, provide assistance (see Chapter 3A, Brief Strategy A4).; - If the patient will participate in an intensive treatment, deliver such a treatment or refer to an intensive intervention (see Chapter 4).; - If the patient clearly states he or she is unwilling to make a quit attempt at this time, provide a motivational intervention (see Chapter 3B).; - If the patient is a member of a special population (e.g., adolescent, pregnant smoker, racial/ethnic minority), consider providing additional information (see Chapter 7).

Brief Strategy A4. Assist -- aid the patient in quitting

Action | Strategies for implementation
Help the patient with a quit plan. | A patient's preparations for quitting:; - Set a quit date -- ideally, the quit date should be within 2 weeks.; - Tell family, friends, and coworkers about quitting and request understanding and support.; - Anticipate challenges to planned quit attempt, particularly during the critical first few weeks. These include nicotine withdrawal symptoms.; - Remove tobacco products from your environment. Prior to quitting, avoid smoking in places where you spend a lot of time (e.g., work, home, car).
Provide practical counseling (problemsolving/ skills training). | Abstinence -- Total abstinence is essential. "Not even a single puff after the quit date." Past quit experience -- Identify what helped and what hurt in previous quit attempts. Anticipate triggers or challenges in upcoming attempt -- Discuss challenges/triggers and how patient will successfully overcome them. Alcohol -- Since alcohol can cause relapse, the patient should consider limiting/abstaining from alcohol while quitting. Other smokers in the household -- Quitting is more difficult when there is another smoker in the household. Patients should encourage housemates to quit with them or not smoke in their presence.
Provide intra-treatment social support | Provide a supportive clinical environment while encouraging the patient in his or her quit attempt. "My office staff and I are available to assist you." (See Table 22)
Help patient obtain extra-treatment social support. | Help patient develop social support for his or her quit attempt in his or her environments outside of treatment. "Ask your spouse/partner, friends, and coworkers to support you in your quit attempt." (See Table 23)
Recommend the use of approved pharmacotherapy, except in special circumstances. | Recommend the use of pharmacotherapies found to be effective in this guideline (see Table 4 for clinical guidelines and Tables 33-39 for specific instructions and precautions). Explain how these medications increase smoking cessation success and reduce withdrawal symptoms. The first-line pharmacotherapy medications include: bupropion SR, nicotine gum, nicotine inhaler, nicotine nasal spray, and nicotine patch.
Provide supplementary materials. | Sources -- Federal agencies, nonprofit agencies, or local/state health departments (see Appendix A for Web site addresses). Type -- Culturally/racially/educationally/age appropriate for the patient. Location -- Readily available at every clinician's workstation.

Brief Strategy A5. Arrange -- schedule followup contact

Action | Strategies for implementation
Schedule followup contact, either in person or via telephone. | Timing -- Followup contact should occur soon after the quit date, preferably during the first week. A second followup contact is recommended within the first month. Schedule further followup contacts as indicated.
Schedule followup contact, either in person or via telephone. | Actions during followup contact -- Congratulate success. If tobacco use has occurred, review circumstances and elicit recommitment to total abstinence. Remind patient that a lapse can be used as a learning experience. Identify problems already encountered and anticipate challenges in the immediate future. Assess pharmacotherapy use and problems. Consider use or referral to more intensive treatment (see Chapter 4).

## B. For the Patient Unwilling To Quit

### Promoting the Motivation To Quit

All patients entering a health care setting should have their tobacco use status assessed routinely. Clinicians should advise all tobacco users to quit and then assess a patient's willingness to make a quit attempt. For patients not ready to make a quit attempt at this time, clinicians should use a brief intervention designed to promote the motivation to quit.

Patients unwilling to make a quit attempt during a visit may lack information about the harmful effects of tobacco, may lack the required financial resources, may have fears or concerns about quitting, or may be demoralized because of previous relapse.^55^ Such patients may respond to a motivational intervention that provides the clinician an opportunity to educate, reassure, and motivate such as the motivational intervention built around the "5 R's": relevance, risks, rewards, roadblocks, and repetition. Clinical components of the "5 R's" are shown in Brief Strategy B below. Motivational interventions are most likely to be successful when the clinician is empathic, promotes patient autonomy (e.g., choice among options), avoids arguments, and supports the patient's self-efficacy (e.g., by identifying previous successes in behavior change efforts).^56,^ ^57,^ ^58^

Brief Strategy B. Enhancing motivation to quit tobacco -- the "5 R's"

Relevance | Encourage the patient to indicate why quitting is personally relevant, being as specific as possible. Motivational information has the greatest impact if it is relevant to a patient's disease status or risk, family or social situation (e.g., having children in the home), health concerns, age, gender, and other important patient characteristics (e.g., prior quitting experience, personal barriers to cessation).
Risks | The clinician should ask the patient to identify potential negative consequences of tobacco use. The clinician may suggest and highlight those that seem most relevant to the patient. The clinician should emphasize that smoking low-tar/low-nicotine cigarettes or use of other forms of tobacco (e.g., smokeless tobacco, cigars, and pipes) will not eliminate these risks. Examples of risks are:; - Acute risks: Shortness of breath, exacerbation of asthma, harm to pregnancy, impotence, infertility, increased serum carbon monoxide.; - Long-term risks: Heart attacks and strokes, lung and other cancers (larynx, oral cavity, pharynx, esophagus, pancreas, bladder, cervix), chronic obstructive pulmonary diseases (chronic bronchitis and emphysema), long-term disability and need for extended care.; - Environmental risks: Increased risk of lung cancer and heart disease in spouses; higher rates of smoking by children of tobacco users; increased risk for low birth weight, SIDS, asthma, middle ear disease, and respiratory infections in children of smokers.
Rewards | The clinician should ask the patient to identify potential benefits of stopping tobacco use. The clinician may suggest and highlight those that seem most relevant to the patient. Examples of rewards follow:; - Improved health.; - Food will taste better.; - Improved sense of smell.; - Save money.; - Feel better about yourself.; - Home, car, clothing, breath will smell better.; - Can stop worrying about quitting.; - Set a good example for children.; - Have healthier babies and children.; - Not worry about exposing others to smoke.; - Feel better physically.; - Perform better in physical activities.; - Reduced wrinkling/aging of skin.
Roadblocks | The clinician should ask the patient to identify barriers or impediments to quitting and note elements of treatment (problemsolving, pharmacotherapy) that could address barriers. Typical barriers might include:; - Withdrawal symptoms.; - Fear of failure.; - Weight gain.; - Lack of support.; - Depression.; - Enjoyment of tobacco.
Repetition | The motivational intervention should be repeated every time an unmotivated patient visits the clinic setting. Tobacco users who have failed in previous quit attempts should be told that most people make repeated quit attempts before they are successful.

## C. For the Patient Who Has Recently Quit

### Preventing Relapse

Because of the chronic relapsing nature of tobacco dependence, clinicians should provide brief effective relapse prevention treatment. When clinicians encounter a patient who has quit tobacco use recently, they should reinforce the patient's decision to quit, review the benefits of quitting, and assist the patient in resolving any residual problems arising from quitting. Although most relapse occurs early in the quitting process,^59,^ ^60^ some relapse occurs months or even years after the quit date.^31,^ ^61^ Therefore, clinicians should engage in relapse prevention interventions even with former tobacco users who no longer consider themselves actively engaged in the quitting process.

Relapse prevention interventions are especially important soon after quitting and can be delivered by means of either scheduled clinic visits, telephone calls, or any time the clinician encounters an ex-tobacco user. A systematic, institutionalized mechanism to identify recent quitters and contact them is essential to deliver relapse prevention messages effectively.

Relapse prevention interventions can be divided into two categories: minimal practice and prescriptive interventions.

#### Minimal Practice Interventions

Minimal practice relapse prevention interventions should be part of every encounter with a patient who has quit recently (Brief Strategy C1). These interventions are appropriate for most recent quitters and can be addressed briefly during a coincident clinic visit or a scheduled followup visit. Because most relapse occurs within the first 3 months after quitting, relapse prevention is especially appropriate during this period.^62,^ ^63^ In addition, strategies designed to reduce relapse should be included in the initial preparation for a quit attempt (see Chapter 3A, Brief Strategy A4. Assist: Aid the patient in quitting, and Chapter 3B, Brief Strategy B. Enhancing motivation to quit tobacco - the "5 R's"). Finally, encourage patients to report difficulties promptly (e.g., lapses, depression, medication side-effects) while continuing efforts to quit.

#### Prescriptive Interventions

Prescriptive relapse prevention components are individualized based on information obtained about problems the patient has encountered in maintaining abstinence (Brief Strategy C2). These more intensive relapse prevention interventions may be delivered during a dedicated followup contact (in-person or by telephone) or through a specialized clinic or program.

### Brief Strategies: Preventing Relapse to Tobacco Use

Brief Strategy C1. Components of minimal practice relapse prevention

These interventions should be part of every encounter with a patient who has quit recently:

Every ex-tobacco user undergoing relapse prevention should receive congratulations on any success and strong encouragement to remain abstinent.

When encountering a recent quitter, use open-ended questions designed to initiate patient problemsolving (e.g., How has stopping tobacco use helped you?). The clinician should encourage the patients' active discussion of the topics below:

- The benefits, including potential health benefits, the patient may derive from cessation.
- Any success the patient has had in quitting (duration of abstinence, reduction in withdrawal, etc.).
- The problems encountered or anticipated threats to maintaining abstinence (e.g., depression, weight gain, alcohol, other tobacco users in the household).

Brief Strategy C2. Components of prescriptive relapse prevention

During prescriptive relapse prevention, a patient might identify a problem that threatens his or her abstinence. Specific problems likely to be reported by patients and potential responses follow:
Lack of support for cessation | - Schedule followup visits or telephone calls with the patient.; - Help the patient identify sources of support within his or her environment.; - Refer the patient to an appropriate organization that offers cessation counseling or support.
Negative mood or depression | - If significant, provide counseling, prescribe appropriate medications, or refer the patient to a specialist.
Strong or prolonged withdrawal symptoms | - If the patient reports prolonged craving or other withdrawal symptoms, consider extending the use of an approved pharmacotherapy or adding/combining pharmacologic medications to reduce strong withdrawal symptoms.
Weight gain | - Recommend starting or increasing physical activity; discourage strict dieting.; - Reassure the patient that some weight gain after quitting is common and appears to be self-limiting.; - Emphasize the importance of a healthy diet.; - Maintain the patient on pharmacotherapy known to delay weight gain (e.g., bupropion SR, NRTs, particularly nicotine gum).; - Refer the patient to a specialist or program.
Flagging motivation/feeling deprived | - Reassure the patient that these feelings are common.; - Recommend rewarding activities.; - Probe to ensure that the patient is not engaged in periodic tobacco use.; - Emphasize that beginning to smoke (even a puff) will increase urges and make quitting more difficult.