# Assessment of Tobacco Use

At least 70 percent of smokers see a physician each year, and more than 50 percent see a dentist.^41,^ ^42,^ ^43^ Other smokers see physician assistants, nurse practitioners, nurses, physical and occupational therapists, pharmacists, and other clinicians. Therefore, all clinicians, particularly physicians and dentists, are uniquely poised to intervene with patients who use tobacco. Moreover, 70 percent of smokers report wanting to quit.^3^ Finally, smokers cite a physician's advice to quit as an important motivator for attempting to stop smoking.^44,^ ^45,^ ^46^ These data suggest that most smokers are interested in quitting, clinicians are frequently in contact with smokers, and clinicians have high credibility with smokers.

Unfortunately, clinicians are not capitalizing on this unique opportunity. More than one-third of current smokers report never having been asked about their smoking status or urged to quit.^11,^ ^47^ Moreover, a population-based survey found that less than 15 percent of smokers who saw a physician in the past year were offered assistance, and only 3 percent had a followup appointment to address tobacco use.^48^ Fewer still have received specific advice on how to quit smoking successfully. This guideline clearly identifies empirically validated tobacco treatment strategies to spur clinicians, tobacco treatment specialists, and administrators to intervene effectively with patients who use tobacco.

The first step in treating tobacco use and dependence is to identify tobacco users. As the data analysis in Chapter 6 shows, the identification of smokers itself increases rates of clinician intervention. Effective identification of tobacco use status not only opens the door for successful interventions (e.g., physician advice), but also it guides clinicians to identify appropriate interventions based on patients' tobacco use status and willingness to quit.

Screening for current or past tobacco use will result in four possible responses: (1) the patient uses tobacco and is now willing to make a quit attempt; (2) the patient uses tobacco but is not now willing to make a quit attempt; (3) the patient once used tobacco but has since quit; and (4) the patient never regularly used tobacco. This clinical practice guideline is organized to provide the clinician with simple, but effective interventions for all of these patients (see Figure 3).

Figure 3. Algorithm for treating tobacco use