# Overview and Methods

## Introduction

Tobacco use has been cited as the chief avoidable cause of illness and death in our society, responsible for more than 430,000 deaths in the United States each year.^1^ Smoking is a known cause of cancer, heart disease, stroke, complications of pregnancy, and chronic obstructive pulmonary disease.^2^ Given the health dangers it presents and the public's awareness of those dangers, tobacco use remains surprisingly prevalent. Recent estimates are that 25 percent of adult Americans smoke.^3,^ ^4,^ ^5^ Moreover, smoking prevalence among adolescents has risen dramatically since 1990,^6^ with more than 3,000 additional children and adolescents becoming regular users of tobacco each day.^7,^ ^8^ As a result, a new generation of Americans has become dependent upon tobacco and is at risk for the extraordinarily harmful consequences of tobacco use.

Tobacco use is not only dangerous to individuals, it also results in staggering societal costs. The estimated smoking-attributable cost for medical care in 1993 was more than $50 billion,^9^ and the cost of lost productivity and forfeited earnings due to smoking-related disability was estimated at $47 billion per year.^10^

Despite the tragic health consequences of using tobacco, clinicians often fail to assess and treat tobacco use consistently and effectively. For instance, in 1995 smoking status was identified in only about 67 percent of clinic visits, and smoking cessation counseling was provided in only 21 percent of smokers' clinic visits.^11^ Moreover, treatment is typically offered only to patients already suffering from tobacco-related diseases.^11^ This failure to assess and intervene consistently with tobacco users exists in the face of substantial evidence that even brief smoking cessation treatments can be effective.^12,^ ^13,^ ^14,^ ^15^

This guideline concludes that tobacco use presents a rare confluence of circumstances: (1) a highly significant health threat; (2) a disinclination among clinicians to intervene consistently; and (3) the presence of effective interventions. This last point is buttressed by evidence that smoking cessation interventions, if delivered in a timely and effective manner, significantly reduce the smoker's risk of suffering from smoking-related disease.^16,^ ^17^ Indeed, it is difficult to identify any other condition that presents such a mix of lethality, prevalence, and neglect, despite effective and readily available interventions.

Finally, significant barriers exist that interfere with clinicians' assessment and treatment of smokers. Many clinicians lack knowledge about how to identify smokers quickly and easily, which treatments are efficacious, how such treatments can be delivered, and the relative efficacies of different treatments.^18^ Additionally, they may fail to intervene because of inadequate clinic or institutional support for routine assessment and treatment of tobacco use^11,^ ^19,^ ^20^ and for other reasons such as time constraints.^21,^ ^22^

## Rationale for Initial Guideline Development and Year 2000 Update

In the early 1990s, the Agency for Health Care Research and Policy (now the Agency for Healthcare Research and Quality [AHRQ]) convened an expert panel to develop the Smoking Cessation Clinical Practice Guideline No. 18 (the "guideline") in the AHCPR series of Clinical Practice Guidelines. The need for this guideline was based on several factors, including tobacco use prevalence, related morbidity and mortality, the economic burden imposed by tobacco use, variation in clinical practice, availability of methods for improvement of care, and availability of data upon which to base recommendations for care.

Since the guideline was published in 1996, it has become a popular document. More than 1 million copies of the guideline and its affiliated products have been disseminated. Guideline recommendations have inspired changes in diverse health care settings such as health maintenance organizations and Veteran's Administration hospitals. The original guideline continues to provide a framework for educating clinicians, administrators, and policymakers about the importance of tobacco dependence and its treatment. It has stimulated discussions that address the development of tobacco dependence treatment programs at the Federal and State levels and by professional medical organizations.

Significant new research on tobacco use and its treatment has appeared since the publication of the original guideline. As a result of this new research, as well as an increasing recognition that tobacco interventions must become an integral part of health care delivery, the expert panel that developed the 1996 Smoking Cessation Clinical Practice Guideline No. 18 was reconvened in 1998 to conduct an update. This guideline update is sponsored by a consortium of private and public partners, including the AHRQ; National Cancer Institute (NCI); National Heart, Lung, and Blood Institute (NHLBI); National Institute on Drug Abuse (NIDA); Office on Smoking and Health at the Centers for Disease Control and Prevention (CDC); Robert Wood Johnson Foundation (RWJF); and University of Wisconsin Medical School's Center for Tobacco Research and Intervention (CTRI).

The original guideline addressed barriers to effective smoking cessation intervention on the basis of a careful evaluation and synthesis of relevant scientific evidence. The guideline comprised specific evidence-based recommendations to guide clinicians and smoking cessation specialists in their tobacco intervention efforts. Additional specific recommendations guided insurers, purchasers, and health care administrators in their efforts to develop and implement institutional and policy changes that support the reliable assessment and treatment of tobacco dependence.

The updated guideline, Treating Tobacco Use and Dependence, a Public Health Service-sponsored Clinical Practice Guideline, provides recommendations based on evidence published through January 1, 1999. This new title underscores three truths about tobacco use.^23^ First, all tobacco products, not just cigarettes, exact devastating costs on the Nation's health and welfare. Second, for most users, tobacco use results in true drug dependence, one comparable to the dependence caused by opiates, amphetamines, and cocaine.^24^ Third, chronic tobacco use warrants clinical intervention just as do other addictive disorders.^18,^ ^25^

Most tobacco users in the United States are cigarette smokers. As a result, the majority of clinician attention and research in the field has focused on the treatment and assessment of smoking. However, clinicians should intervene with all tobacco users, not just with smokers. To foster a broad implementation of this guideline, every effort has been made to describe interventions so that they are relevant to all forms of tobacco use. In some sections of this guideline (e.g., sections of Chapter 6), the term "smoker" is used instead of "tobacco user." The use of the term "smoker" merely means that all relevant evidence for a recommendation arises exclusively from studies of cigarette smokers. Additional discussion of noncigarette forms of tobacco use is found in Chapter 8.

It is important to note that other guidelines and analyses on the treatment of tobacco dependence have been published, including those from the American Psychiatric Association,^26^ the American Medical Association,^27^ the United Kingdom Guideline,^28^ and those published by the Cochrane Collaboration.^29^

## Tobacco Dependence as a Chronic Disease

Tobacco dependence shows many features of a chronic disease. Although a minority of tobacco users achieves permanent abstinence in an initial quit attempt, the majority persist in tobacco use for many years and typically cycle through multiple periods of relapse and remission. A failure to appreciate the chronic nature of tobacco dependence may undercut clinicians' motivation to treat tobacco use consistently.

Epidemiologic data suggest that more than 70 percent of the 50 million smokers in the United States today have made at least one prior quit attempt, and approximately 46 percent try to quit each year.^4^ Unfortunately, most of these efforts are unsuccessful; among the 17 million adults who attempted cessation in 1991, only about 7 percent were still abstinent 1 year later.^30,^ ^31^ These discouraging statistics have led many clinicians to report that they feel ineffective in the treatment of tobacco dependence.

Moreover, as described in a recent editorial,^32^ much smoking cessation research and clinical practice over the last three decades has focused on identifying the ideal intervention that would turn all smokers into permanent nonsmokers. This effort may have inadvertently communicated two messages of dubious validity: first, that there is one treatment that will be effective for virtually all smokers; and second, that success should be defined only on the basis of permanent abstinence. These messages may have masked the true nature of tobacco addiction; it is typically a chronic disorder that carries with it a vulnerability to relapse that persists for weeks, months, and perhaps years.

A more productive approach is to recognize the chronicity of tobacco dependence. A chronic disease model has many appealing aspects. It recognizes the long-term nature of the disorder with an expectation that patients may have periods of relapse and remission. If tobacco dependence is recognized as a chronic condition, clinicians will better understand the relapsing nature of the ailment and the requirement for ongoing, rather than just acute, care. Clinicians also should recognize that despite the potential for relapse, numerous effective treatments are now available and described in this guideline.

A chronic disease model emphasizes for clinicians the importance of counseling and advice. Although most clinicians are comfortable in counseling their patients about diabetes, hypertension, or hyperlipidemia, many believe that they are ineffective in providing counseling to patients who use tobacco. As with these chronic disorders, clinicians encountering a patient dependent on tobacco must be encouraged to provide that patient with simple counseling advice, support, and appropriate pharmacotherapy. In updating the guideline, the panel has presented evidence-based analytic findings in a format accessible and familiar to practicing clinicians. Although this should aid clinicians in the assessment and treatment of tobacco users, clinicians should remain cognizant that relapse is likely, and that it reflects the chronic nature of dependence, not their personal failure, nor a failure of their patients.

## Guideline Development Methodology

### Introduction

Panel recommendations are intended to provide clinicians with effective strategies for treating patients who use tobacco. Recommendations were influenced by two goals. The first was to identify clearly efficacious treatment strategies. The second was to formulate and present recommendations so that they can be implemented easily across diverse clinical settings and patient populations.

The guideline is based on two systematic reviews of the available scientific literature. The first review occurred during the creation of the original guideline published in 1996 and included literature published from 1975 through 1994. The second review was conducted for the updated guideline and included literature from 1995 through January 1, 1999. The two reviews were then combined into a single database.

The panel identified randomized placebo/comparison controlled trials as the strongest level of evidence for evaluation of treatment efficacy. Thus, evidence derived from randomized controlled trials serves as the basis for meta-analyses and for almost all recommendations contained in this guideline. However, the panel occasionally made recommendations in the absence of randomized controlled trials. It did so when faced with an important clinical practice issue for which persuasive evidence existed. When the panel considered evidence other than randomized controlled trials, it did not restrict itself to articles that otherwise met the inclusion criteria. For example, for recommendations that were not based on meta-analyses, the panel reviewed some articles published after January 1, 1999. This guideline clearly identifies the level or strength of evidence that serves as the basis for each of its recommendations.

### Topics Included in the Guideline

The panel identified tobacco use as the targeted behavior and tobacco users as the clinical population of interest. Tobacco dependence treatments were evaluated for efficacy as were interventions aimed at modifying both clinician and health care delivery system behavior.

Interventions for the primary prevention of tobacco use were not examined in detail with the exception of interventions directly relevant to clinical practice. Because of the importance and complexity of the primary prevention of tobacco initiation, the panel recommends that primary prevention be addressed in a separate clinical practice guideline. Readers may also refer to the 1994 Surgeon General's Report, Preventing Tobacco Use Among Young People.^63^ In addition, community-level interventions (e.g., mass media campaigns) that are not usually implemented in primary care practice settings are not addressed. For more information on community-based tobacco use prevention, refer to the Centers for Disease Control and Prevention Guide to Community Preventive Services (available in 2000).

This guideline is designed for three main audiences: primary care clinicians; tobacco dependence treatment specialists; and health care administrators, insurers, and purchasers. Additionally, the guideline is designed to be used in a wide variety of clinical practice settings, including private practices, academic health centers, managed care settings and health maintenance organizations, public health department clinics, hospitals, and school or work site clinics.

At the start of the update process, guideline panel members, outside experts, and consortium representatives were consulted to determine those aspects of the original guideline that required updating. These consultations resulted in the following chief recommendations that guided the update efforts: (1) to update any recommendations from the original guideline likely to be affected by new research findings; (2) to provide information and recommendations on health systems changes relevant to tobacco cessation including the cost-effectiveness of tobacco cessation; (3) to summarize the literature and make recommendations regarding special populations; and (4) to address content areas and models of treatment for which little data existed during the development of the original guideline.

### Guideline Development Process

The original guideline development process was initiated in late 1993. This update was initiated in mid-1998. The methodology was consistent between the two efforts except where specifically identified below (see Figure 1).

Figure 1. Guideline development process ^a^

^a^ These steps were taken in drafting both the original and updated guidelines.

### Selection of Evidence

Published, peer-reviewed, randomized controlled studies were considered to constitute the strongest level of evidence in support of guideline recommendations. This decision was based on the judgment that randomized controlled trials provide the clearest, scientifically sound basis for judging comparative efficacy. The panel made this decision recognizing the limitations of randomized controlled trials, particularly considerations of generalizability with respect to patient selection and treatment quality.

### Literature Review and Inclusion Criteria

Approximately 6,000 articles were reviewed to identify evaluable literature—3,000 during the original project and another 3,000 during the update. These articles were obtained through searches of electronic databases and reviews of published abstracts and bibliographies. An article was deemed appropriate for meta-analysis if it met the criteria for inclusion established a priori by the panel. These criteria were that the article: (a) reported the results of a randomized, placebo/comparison controlled trial of a tobacco-use treatment intervention randomized on the patient level; (b) provided followup results at a timepoint at least 5 months after the quit date; (c) was published in a peer-reviewed journal; (d) was published between January 1, 1975 and January 1, 1999; and (e) was published in English. Additionally, articles screened during the update were screened for relevance to economic or health systems issues. As a result of the original and update literature reviews, more than 180 articles were identified for possible inclusion in a meta-analysis, and more than 500 additional articles were examined by the panel. These articles were used in the consideration and formulation of panel recommendations that were not supported by meta-analyses. The literature search for the update project was validated by comparing the results against a search conducted by the CDC, by a review of the database by the expert panel, and by requesting articles pertaining to special topics from experts in the field.

It is important to note that due to a faithful application of article screening criteria in the updated guideline, some of the studies that were included in the original guideline were not included in the updated analyses. This resulted in an inability to perform certain analyses that had previously been conducted (e.g., analysis of the different types of self-help).

When individual authors published multiple articles meeting the meta-analytic inclusion criteria, the articles were screened to determine whether they contained unique data. Where two articles reported data from the same group of subjects, both articles were used to elicit the complete trial data for the analyses.

### Preparation of Evidence Tables

Three reviewers independently read and coded each article that met inclusion criteria. The reviewers coded the treatment characteristics that were used in data analyses (see Table 6 in Chapter 6). The same general coding procedure employed during the original guideline process was employed during the update. Where adjustments to the coding process were made, articles from the original process were re-coded to reflect the changed coding (e.g., more refined counseling and behavioral therapy designations were used during the update to capture more specific counseling practices.) The reviewers then met and compared coding. Any discrepancies that could not be resolved were adjudicated by the project director, panel chair, and/or senior scientific consultant. The data were then compiled and used in relevant analyses. As a test of the coding process for the update, inter-rater reliability analyses were conducted on four coded intervention categories: type of format, type of clinician, type of counseling and behavioral therapies, and level of person-to-person contact. Using the proportional overlap method^33^ for format, clinician and counseling and behavioral therapies, and the nominal response method^34^ for level of person-to-person contact, reliability analyses were conducted on 16 studies that had all been coded by the same three reviewers. Coded data were sampled from the preadjudicated ratings made by the three reviewers who coded the greatest number of articles. Studies and intervention categories were selected after coding, so reviewers were unaware of the data to be analyzed for reliability. Results revealed the following chance-corrected inter-rater reliabilities for each of the tested categories: kappa = .73 for format, kappa = .72 for clinician, kappa = .77 for counseling and behavioral therapies, and kappa = .78 for level of person-to-person contact.

Table 6. Treatment and assessment characteristics analyzed for their relation to abstinence outcomes

Characteristics analyzed | Categories of those characteristics
Screen for tobacco use | No screening system in place. Screening system in place.
Advice to quit | No advice to quit. Physician advice to quit.
Intensity of person-to-person clinical contact | No person-to-person intervention. Minimal counseling (longest session < 3 min in duration). Low intensity counseling (longest session > 3 min and < 10 min in duration). Higher intensity counseling (longest session > 10 min). Total amount of contact time. Number of person-to-person treatment sessions.
Type of clinician | No clinician. Self-help materials only. Nonphysician health care clinician (e.g., psychologist, counselor, social worker, nurse, dentist, graduate student, pharmacist). Physician. Number of types of clinicians.
Formats of psychosocial intervention | No contact. Self-help/self-administered (e.g., pamphlet, audiotape, videotape, mailed information, computer program). Individual counseling/contact. Group counseling/contact. Proactive telephone counseling/contact. Number of types of formats.
Self-help interventions | Number of self-help interventions. Self-help interventions.
Types of counseling and behavioral therapies | No person-to-person intervention or minimal counseling. General -- problemsolving/coping skills/relapse prevention/stress management approach. Negative affect/depression intervention. Weight/diet/nutrition intervention. Extra-treatment social support intervention. Intra-treatment social support intervention. Contingency contracting/instrumental contingencies. Rapid smoking. Other aversive smoking techniques. Cigarette fading/smoking reduction prequit. Acupuncture.
Pharmacologic interventions | Placebo pharmacotherapy. Bupropion SR. Clonidine. Nicotine gum. Nicotine inhaler. Nicotine nasal spray. Nicotine patch. Nortriptyline.
Combination nicotine replacement therapy | One nicotine replacement therapy. Two nicotine replacement therapies.
Over-the-counter pharmacotherapy | Placebo over-the-counter nicotine patch therapy. Over-the-counter nicotine patch therapy.

### Outcome Data

To meet inclusion criteria for the meta-analyses, a study was required to provide outcome data with followup at least 5 months after the designated quit day. Five months was chosen to balance the needs for (a) a large pool of studies for meta-analyses and (b) the desire to examine only clinically important outcomes (i.e., long-term abstinence). When quit rates were provided for multiple long-term endpoints, efficacy data from the endpoint closest to 6 months were used, so long as they did not exceed 3 years. Virtually all cessation analyses in this guideline were done on these long-term outcome data. (One exception is that the meta-analysis of cessation treatments in pregnant women allowed somewhat shorter followup periods because of the desire for preparturition data.)

Panel staff also coded biochemical confirmation of self-reported abstinence. Previous guideline analyses show that studies with, and without, biochemical confirmation yield similar meta-analysis results. Therefore, meta-analyses presented in the guideline reflect a pooling of these studies. The only exception to this was in the pregnancy analyses. Data suggest that self-reported abstinence rates may be less reliable in pregnant women; therefore, the pregnancy meta-analysis included only abstinence data that were biochemically confirmed.^35,^ ^36,^ ^37^

Two types of followup data were included in the analyses to index treatment efficacy. The first and preferred type of data was intent-to-treat data, in which the denominator was the number of patients randomized to treatment and the numerator was the number of abstinent patients contacted at followup. The second type of acceptable data was similar, except that the denominator consisted only of patients who had completed treatment. Other types of followup data were not included in analyses (e.g., studies in which the denominator included only those subjects contacted during followup).

Studies were coded for how the outcome measures were reported, "point prevalence," "continuous," or "unknown." If abstinence data were based on smoking occurrence within a set time period (usually 7 days) prior to a followup assessment, the outcome measure was coded as "point prevalence." "Continuous" was used when a study reported abstinence based on whether study subjects were continuously abstinent from tobacco use since their quit day. "Unknown" was used when it was not possible to discern from the study report whether the authors used a point prevalence or continuous measure for abstinence.

As in the original guideline, a point prevalence outcome measure (1-week point prevalence, when available) rather than continuous abstinence was used as the chief outcome variable. Point prevalence was preferred for several reasons. First, among the 180 randomized controlled trials available for meta-analysis, the majority presented their primary outcome data as point prevalence. Second, continuous abstinence data underestimate the percentage of individuals who are abstinent at particular followup timepoints. They might, therefore, suggest that the likelihood of cessation is lower than in actuality. Finally, most relapse begins early in a quit attempt and persists. A point prevalence measure taken at 5 months would certainly capture the great majority of those relapse events. Therefore, wherever possible, 1-week point prevalence abstinence data were used. If point prevalence data were not available, the preferred alternative was continuous abstinence data. Data of an unknown or unspecified nature were used otherwise.

### Meta-Analytic Techniques

The principal analytic technique used in this guideline was meta-analysis. This statistical technique estimates the impact of a treatment or variable across a set of related investigations. The primary meta-analytic model used in this and the original guideline was logistic regression using random effects modeling. The modeling was done at the level of the treatment arm, and study effects were treated as fixed. The panel methodologists chose to employ random effects modeling, assuming that both the subject populations and the treatment elements analyzed would vary from study to study (e.g., "general problemsolving" counseling might be done somewhat differently at two different sites). Random effects modeling is well suited to accommodate such variation among studies.^38^ The statistician used the EGRET Logistic Normal Model (Statistics and Epidemiology Research Corporation, EGRET Reference Manual, Revision 4, Seattle, 1993). A complete and detailed review of the meta-analytic methods used in the guideline can be found in the Smoking Cessation Guideline Technical Report No. 18 available from AHRQ as AHCPR Publication No. 97-N004.

The meta-analytic technique assumed randomization of subjects to treatment conditions. Moreover, studies that randomized at another level (e.g., clinician, clinic, etc.) typically did not provide data on nonindependence. Therefore, only studies that randomized at the level of the subject were submitted to meta-analysis. To reduce the likelihood that this selection criterion would bias results, some test analyses were performed that included studies randomized by clinic or clinician. In all cases, these analyses were consistent with the results of studies using subject-based randomization.

The initial step in meta-analysis was the selection of studies that were relevant to the treatment characteristic being evaluated. After relevant studies were identified (e.g., those that contained a self-help intervention if self-help treatments were being evaluated), panel staff reviewed the studies to ensure that they passed screening criteria. Some screening criteria were general (e.g., study presents greater than 5 months followup data), whereas other criteria were specific to the type of treatment characteristic evaluated (e.g., in the analysis of clinicians, screening ensured that differences in type of clinician were not confounded by differences in use of pharmacotherapy). In most cases, there was no attempt to control for the effects of variables that were potentially correlated with an analyzed treatment dimension (e.g., controlling for overall treatment intensity in the analysis of number of types of formats and number of types of clinicians).

The separate arms (treatment or control groups) in each study were then inspected to identify confounders that could compromise interpretation. Seriously confounded arms were excluded from analysis. Relevant characteristics of each arm were then coded to produce meaningful analytic comparisons. Criteria for performing a meta-analysis included: (1) the guideline panel judged the topic to be addressed in the meta-analysis as having substantial clinical significance; (2) at least two studies meeting selection criteria existed on the topic and the studies contained suitable within-study control or comparison conditions; and (3) there was acceptable inter-study homogeneity in the analyzed variable or treatment to permit meaningful inference (e.g., an analyzed treatment was sufficiently similar across various studies so that combining studies was meaningful).

#### Limitations of Meta-Analytic Techniques

Several factors can compromise the internal validity of meta-analyses. For example, publication biases (particularly the tendency to publish only those studies with positive findings) may result in biased summary statistics. The complement to publication bias is the "file-drawer effect," in which negative or neutral findings are not submitted for publication. In addition, either the magnitude or the significance of the effects of meta-analyses may be influenced by factors such as the frequency with which treatments occurred in the data set, and by the extent to which treatments co-occurred with other treatments. All else being equal, a treatment that occurs infrequently in the data set is less likely to be found significant than a more frequently occurring treatment. Also, when two treatments co-occur frequently in the same groups of subjects, it is difficult to apportion statistically the impact of each. In addition, comparability biases can exist when substantially different groups or treatments are coded as being the same (e.g., when treatments are similar only on a superficial attribute).

Stability of meta-analytic findings was determined with respect to only one population characteristic, that is whether patients sought cessation treatment ("self-selected") or whether treatment was delivered without the patient seeking it ("all-comers," as when cessation treatment occurred as an integral part of health care). Conducting separate meta-analyses in these different subject populations yielded very similar findings across a variety of treatment dimensions (e.g., treatment format, treatment intensity). No other population characteristic (e.g., years smoked, severity of dependence) was explored in meta-analyses.

#### Interpretation of Meta-Analysis Results

The meta-analyses yielded logistic regression coefficients that were converted to odds ratios. The meaning or interpretation of an odds ratio can be seen most easily by means of an example depicted in a 2 X 2 table. Table 1 contains data showing the relation between maternal smoking and low birth weight in infants. Data are extracted from Hosmer and Lemeshow.^39^ The odds of a low birth weight infant if the mother smokes are 30:44, or 0.68 to 1. The odds of a low birth weight infant if the mother does not smoke are 29:86, or 0.34 to 1. The odds ratio is thus (30/44)/(29/86) = 2.02 to 1. Therefore, the odds ratio can be seen roughly as the odds of an outcome on one variable, given a certain status on another variable(s). In the case above, the odds of a low birth weight infant is about double for women who smoke compared with those who do not.

Table 1. Relation between maternal smoking and low birth weight in infants

| | Maternal smoking
| | Yes | No
Low birth weight | Yes | 30 | 29 | 59
| No | 44 | 86 | 130
| | 74 | 115 | 189

Once odds ratios were obtained from meta-analyses, 95 percent confidence intervals were estimated around the odds ratios. An odds ratio is only an estimate of a relation between variables. The 95 percent confidence interval presents an estimate of the accuracy of the particular odds ratio obtained. If the 95 percent confidence interval for a given odds ratio does not include "1," then the odds ratio represents a statistically significant effect at the .05 level. The confidence intervals will generally not be perfectly symmetrical around an odds ratio because of the distributional properties of the odds ratio. Comparisons of the relative sizes of odds ratios is meaningful only for those odds ratios yielded by the same meta-analysis (listed in the same data table).

After computing the odds ratios and their confidence intervals, the odds ratios were converted to abstinence percentages and their 95 percent confidence intervals (based on reference category abstinence rates). Abstinence percentages indicate the estimated long-term abstinence rate achieved under the tested treatment or treatment characteristic. The abstinence percentage results are approximate estimates derived from the odds ratio data.^40^ Therefore, they essentially duplicate the odds ratio results but are presented because their meaning may be clearer for some readers. Because the placebo/control abstinence percentage for a particular analysis is calculated exclusively from the studies included within that meta-analysis, these abstinence percentages vary across the different analyses.

### How To Read the Data Tables

Table 2 depicts a table of results from one of the meta-analyses reported in this guideline. This table presents results from the analysis of the effects of different treatment formats on outcome (see Formats of Psychosocial Treatments in Chapter 6B). In this table, the comparison condition, or "reference group," for determining the impact of different treatment options, was smokers who had no contact with a provider. The "Estimated odds ratio" column reveals that treatment groups receiving self-help treatment had an odds ratio of 1.2. The odds ratio indicates a significant effect, because the lower boundary of the confidence interval did not include "1." Proactive phone counseling had an odds ratio of 1.2, and group counseling had an odds ratio of 1.3. Both of these are statistically significant because the lower bounds of their confidence intervals do not include "1". Individual counseling had the largest odds ratio of 1.7. This odds ratio means that when a smoker receives individual counseling, he or she is more than one and one-half times more likely to remain abstinent than if he or she had received no counseling.

Table 2. Meta-analysis: Efficacy of and estimated abstinence rates for various types of format (n = 58 studies)

Format | Number of arms | Estimated odds ratio (95% C.I.) | Estimated abstinence rate (95% C.I.)
No format | 20 | 1.0 | 10.8
Self-help | 93 | 1.2 (1.02, 1.3) | 12.3 (10.9, 13.6)
Proactive telephone counseling | 26 | 1.2 (1.1, 1.4) | 13.1 (11.4, 14.8)
Group counseling | 52 | 1.3 (1.1, 1.6) | 13.9 (11.6, 16.1)
Individual counseling | 67 | 1.7 (1.4, 2.0) | 16.8 (14.7, 19.1)

The column labeled "Estimated abstinence rate" shows the abstinence percentages for the various treatment formats. For instance, the reference group conditions (no contact) in the analyzed data set were associated with an abstinence rate of 10.8 percent. Consistent with the odds ratio data reviewed above, self-help treatments produced modest increases in abstinence rates (12.3 percent), proactive phone counseling and group counseling produced somewhat larger increases in abstinence rates (13.1 percent and 13.9 percent respectively), and individual counseling produced the largest increase (16.8 percent).

The total number of studies included in each meta-analysis is provided within the title of the corresponding table. A list of published articles used in each meta-analysis is available from AHRQ via the AHRQ Web site at www.ahrq.gov.

The column labeled "Number of arms" lists the number of treatment conditions or groups across all analyzed studies that contributed data to the various treatment format categories (e.g., self-help treatment was provided in 93 treatment arms). Therefore, this column depicts the number of treatment conditions or groups relevant to each analyzed category. Frequently, the number of treatment groups or arms exceeds the number of studies included in a meta-analysis.

The outcome data in the tables include studies with "all-comers" (individuals who did not seek a treatment intervention) and "self-selected" populations, studies using point-prevalence and continuous abstinence endpoints, and studies with and without biochemical confirmation, except where otherwise described. Some meta-analyses (such as those evaluating pharmacotherapies) included predominantly studies with "self-selected" populations. In addition, in pharmacotherapy studies both experimental and control subjects typically received substantial counseling. Both of these factors tend to produce higher abstinence rates in reference or placebo subjects than are typically observed among self-quitters.

### Strength of Evidence

Every recommendation made by the panel bears a strength-of-evidence rating that indicates the quality and quantity of empirical support for the recommendation. Each recommendation and its strength of evidence reflect consensus of the guideline panel. The three strength of evidence ratings are described below:

1. Multiple well-designed randomized clinical trials, directly relevant to the recommendation, yielded a consistent pattern of findings.
2. Some evidence from randomized clinical trials supported the recommendation, but the scientific support was not optimal. For instance, few randomized trials existed, the trials that did exist were somewhat inconsistent, or the trials were not directly relevant to the recommendation.
3. Reserved for important clinical situations where the panel achieved consensus on the recommendation in the absence of relevant randomized controlled trials.

The availability of randomized clinical trials was not considered in economic recommendations. The existence of such trials was thought to be a less germane criterion for evaluating economic studies. In such cases, the strength of evidence is based primarily on the consistency of findings among different studies. Finally, the panel declined to make recommendations when there was no relevant evidence or the evidence was too weak or inconsistent to support a recommendation.

### Caveats Regarding Recommendations

The reader should note some caveats regarding guideline recommendations. First, an absence of studies should not be confused with proven lack of efficacy. In certain situations, there was little direct evidence regarding the efficacy of some treatments, and in these cases the panel usually rendered no opinion. Second, even when there were enough studies to perform a meta-analysis, a nonsignificant result does not prove inefficacy. Rather, nonsignificance merely indicates that efficacy was not demonstrated given the data available.

The emphasis of this guideline was to identify efficacious interventions, not to rank-order interventions in terms of efficacy. The panel chose not to emphasize comparisons among efficacious interventions for several reasons. First, the most important goal of the analytic process was to identify all efficacious interventions. Second, selection or use of particular intervention techniques or strategies is usually a function of practical factors: patient preference, time available, training of the clinician, cost, and so on. The panel believed clinicians should choose the most appropriate intervention from among the efficacious interventions, given existing circumstances. An excessive emphasis on relative efficacy might discourage clinicians from using interventions that have a small, but reliable, impact on smoking cessation. Finally, data were often inadequate or unavailable to make adequate statistical comparisons of different types of interventions. For example, there were insufficient studies testing head-to-head comparisons of the different pharmacotherapies to allow a rank-ordering of the different pharmacotherapies.

Despite a lack of emphasis on the rank-ordering of interventions, some interventions were so superior to control or no-treatment conditions that the panel clearly identified them as superior to another intervention. For instance, although minimal person-to-person contact can increase smoking abstinence rates over no-treatment conditions, there is little doubt that longer person-to-person interventions have greater impact.

### External Review of the Guideline

The panel and AHRQ invited 155 outside reviewers to review the draft of the 1996 guideline. In addition, AHRQ placed a notice in the Federal Register inviting individuals to review and comment on this original draft guideline. A total of 71 reviewers provided comments. Panel and consortium members invited 175 outside reviewers to review the updated guideline. A total of 70 provided comments. Peer reviewers included clinicians, health care administrators, social workers, counselors, health educators, researchers, consumers, key personnel at selected Federal agencies, and others. Reviewers were asked to evaluate the guideline based on five criteria: validity, reliability, clarity, clinical applicability, and utility. Comments of the peer reviewers were incorporated into the guideline when appropriate.

## Guideline Products

Accompanying the original guideline were four products intended to aid in the dissemination and translation of the guideline's evidence-based recommendations. These products were intended to address consumers as well as the three target audiences: primary care clinicians, specialists, health care administrators, insurers, and purchasers. These products were: (1) You Can Quit Smoking. Consumer Guide; (2) Helping Smokers Quit. A Guide for Primary Care Clinicians; (3) Smoking Cessation: Information for Specialists. Quick Reference Guide; and (4) Smoking Cessation, A Systems Approach: A Guide for Health Care Administrators, Insurers, Manage Care Organizations, and Purchasers. Similar products will disseminate the recommendations of the updated guideline.

## Organization of the Guideline Update

This updated guideline is divided into eight chapters that reflect the major components of tobacco dependence treatment (see Figure 2 for treatment model):

Figure 2. Model for treatment of tobacco use and dependence

Chapter 1, Overview and Methods, provides an overview and rationale for the updated guideline, as well as a detailed description of the methodology used to review the scientific literature and develop the original and updated guidelines.

Chapter 2, Assessment of Tobacco Use, establishes the importance of determining the tobacco use status of every patient at every visit.

Chapter 3, Brief Clinical Interventions, is intended to provide clinicians with guidance as they use brief interventions to treat tobacco users willing to quit, tobacco users unwilling to make a quit attempt at this time, and tobacco users who have recently quit.

A. For the Patient Willing To Quit, provides brief clinical approaches to assist patients in quit attempts.
B. For the Patient Unwilling To Quit, provides brief clinical approaches designed to motivate the patient to make a quit attempt at this time.
C. For the Patient Who Has Recently Quit, provides clinicians with brief strategies designed to reinforce an ex-tobacco user's commitment to stay tobacco-free.

Chapter 4, Intensive Clinical Interventions, provides clinicians with more intensive strategies to treat tobacco users.

Chapter 5, Systems Interventions: Relevance to Health Care Administrators, Insurers, and Purchasers, is directed at health care administrators, insurers, purchasers, and other decisionmakers who can affect health care systems. This chapter provides these decisionmakers with strategies to modify health care systems to improve the delivery of tobacco treatment services.

Chapter 6, Evidence, presents the evidentiary basis for the updated guideline recommendations.

A. Screening and Assessment, provides recommendations and analysis results regarding screening for tobacco use and specialized assessment.
B. Treatment Structure and Intensity, provides recommendations and analysis results regarding advice, intensity of clinical interventions, and type of clinician, format, and followup procedures.
C. Treatment Elements, provides recommendations and analysis results regarding types of counseling and behavioral therapies and pharmacotherapy.

Chapter 7, Special Populations, provides information on specific populations such as women, pregnant tobacco users, racial and ethnic minorities, hospitalized patients, older adults, tobacco users with other chemical dependencies, and children and adolescents.

Chapter 8, Special Topics, provides specific information on topics not otherwise addressed in the updated guideline such as weight gain associated with tobacco cessation, noncigarette tobacco products, clinician training, and reimbursement for tobacco cessation treatment.