# Financial Disclosures for Panel Members, Consultants, and Senior Project Staff

## Panel Members

Michael C. Fiore has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by Ciba-Geigy, SmithKline Beecham, Lederle Laboratories, McNeil, Elan Pharmaceutical, and Glaxo Wellcome.

William C. Bailey has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by Glaxo Wellcome, SmithKline Beecham, Schering-Plough, 3M Pharmaceuticals, Pfizer, and Sepracor.

Stuart J. Cohen has not served as a consultant for, given lectures sponsored by, or conducted research sponsored by any pharmaceutical company.

Sally Faith Dorfman has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by various pharmaceutical companies.

Michael G. Goldstein, in addition to being an employee of the Bayer Corporation, has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by Glaxo Wellcome, McNeil, Ciba-Geigy, SmithKline Beecham, Boehringer Ingelheim, Sano Corporation, Dupont Pharmaceuticals, and Eli Lilly.

Ellen R. Gritz has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by Bristol Myers Squibb, SmithKline Beecham, and Glaxo Wellcome.

Richard B. Heyman has not served as a consultant for, given lectures sponsored by, or conducted research sponsored by any pharmaceutical company.

Carlos Roberto Jaén has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by Glaxo Wellcome Pharmaceuticals.

Thomas E. Kottke has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by McNeil Consumer Healthcare.

Harry A. Lando has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by Glaxo Wellcome and SmithKline Beecham.

Robert Mecklenburg has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by SmithKline Beecham and Glaxo Wellcome.

Patricia Dolan Mullen has not served as a consultant for, given lectures sponsored by, or has conducted research sponsored by any pharmaceutical companies.

Louise M. Nett has not served as a consultant for, given lectures sponsored by, or conducted research sponsored by any pharmaceutical company.

Lawrence Robinson has not served as a consultant for, given lectures sponsored by, or conducted research sponsored by any pharmaceutical company.

Maxine L. Stitzer has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by McNeil and SmithKline Beecham.

Anthony C. Tommasello has not served as a consultant for, given lectures sponsored by, or conducted research sponsored by any pharmaceutical company.

Louise Villejo has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by Ortho Biotech.

Mary Ellen Wewers has not served as a consultant for, given lectures sponsored by, or conducted research sponsored by any pharmaceutical company.

## Consultants

Timothy Baker has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by Elan Pharmaceutical, SmithKline Beecham, Glaxo Wellcome, and Lederle.

Victor Hasselblad has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by CorTheraputics, Skinceuticals, Merck, Novartis, AstraZeneca, AstraCharnwood, The Medicines, Pfizer, Daiichi, Hoffman-LaRoche, RhonePolenc Rorer, Alexion, SmithKline Beecham, Dade, Quad-C, and Centocor Lilly.

Marc Manley has not served as a consultant for, given lectures sponsored by, or conducted research sponsored by any pharmaceutical company.

David L. Schriger has served as a consultant for, given lectures sponsored by, or has conducted research sponsored by Pfizer Corporation and the MedAmerica Corporation.

David W. Wetter has not served as a consultant for, given lectures sponsored by, or conducted research sponsored by any pharmaceutical company.

## Senior Project Staff

Brion J. Fox has not served as a consultant for, given lectures sponsored by, or has conducted research sponsored by any pharmaceutical company.